# DATA ABSTRACTION FOR PRIMARY STUDIES OBTAINED FROM GOOD QUALITY SYSTEMATIC REVIEWS^a^ a Good quality systematic reviews were defined as scoring 6 or higher (on a 7-point scale) according to the Oxman and Guyatt 1991 criteria.8