# CRITERIA USED IN QUALITY ASSESSMENT OF PRIMARY STUDIES RELATED TO ADDITIONAL RISK FACTORS TO PREDICT SUICIDAL SELF-DIRECTED VIOLENCE^a^ a Modified from Hayden et al. 2006 and Harris et al. 2001.^9, 10^

Domain | | Description
1. | Adequate description of population | Study describes inclusion criteria for selecting patients, demographics (at least age), and setting (primary care vs. hospital vs. other).
2. | Non-biased selection | Study either reports enrolling (or attempting to enroll) a consecutive series of patients meeting inclusion criteria, or a random sample (was any group of patients systematically excluded?)
3. | Low loss to follow-up/missing data adequately described? (Yes/Partly/No/Unsure) | Was there low overall missing data and no differences between comparison groups in missing data? Was there an adequate description of the handling of missing data? Numbers should be given for each group.
4. | Adequate/unbiased risk factor measurement? (Yes/Partly/No/Unsure) | Study describes reproducible and appropriate methods for measuring prognostic factors. Note the inadequate factors as applicable (e.g., depression without description of measurement method or use of inferior method such as self-report).
5. | Adequate/unbiased outcome measurement? (Yes/Partly/No/Unsure) | Study clearly describes reproducible and appropriate methods to identify/define the events - suicide attempt or behavior. Were methods objective or self-report?
6. | Was the sample size adequate (including adequate number of outcome events)? (Yes/No/Unsure) | Study has adequate participant numbers to assess differences in suicide rates based on risk factors. Studies of higher risk populations (psychiatric disorders, prior suicide attempts) may need fewer people to have adequate sample size.
7. | Adequate statistical adjustment | Study performs statistical adjustment or controls for one or more potential confounders using acceptable statistical methods (must include 1 of the following: suicidal ideation, any mental health diagnosis, prior suicide attempt, substance abuse).
8. | Number of required confounders adjusted for in analysis | Count of the confounders reported in #7 (total possible = 4).
9. | External validity | Is the population relevant to the population of interest? Describe.