# CRITERIA USED IN QUALITY ASSESSMENT OF PRIMARY STUDIES RELATED TO ASSESSING RISK OF ENGAGING IN SUICIDAL SELF-DIRECTED VIOLENCE^a^ a Modified from Hayden et al. 2006 and Harris et al. 2001.^9, 10^

Domain | | Description
1. | Adequate description of population | Study describes inclusion criteria for selecting patients, demographics (at least age), and setting (primary care vs. hospital vs. other).
2. | Non-biased selection | Study either reports enrolling (or attempting to enroll) a consecutive series of patients meeting inclusion criteria, or a random sample.
3. | Low loss to follow-up/missing data? | Was there important differential loss to follow-up or overall high loss to follow-up? Numbers should be given for each group.
4a. | Standardized method of risk factor assessment and scoring clearly described or referenced. | Standardized, reproducible methods of assessment and scoring must be reported or referenced.
4b. | Unbiased risk factor assessment by independent assessors? | Study describes unbiased risk factor assessment by independent assessors.
5a. | Adequate outcome measurement? | Study clearly describes standardized and reproducible methods to identify/define the events - suicide attempt or behavior - in the entire population of eligible participants regardless of initial risk assessment.
5b. | Unbiased outcome measurement by independent assessors? | Study clearly describes unbiased methods to identify/define the events - suicide attempt or behavior - by independent assessors.
6. | Adequate accounting for potential confounders? | Potential confounders are accounted for by a comparable control group or statistical methods of adjustment.