# STUDY SELECTION FORM

## VA ESP Suicide Prevention Study Selection Process: Coding

### Step 1 Importing citations

- Enter database name, search date, and other details into Custom 1.

### Step 2 Title/Abstract level coding

- The objective of the title/abstract review phase is to eliminate obviously irrelevant publications. Abstracts that lack an explicit reference to suicidal self-directed violence (e.g., suicidality, behaviors, attempts, and suicides) will be excluded at this phase. Reviewers will provide decision and characteristic codes and these will be recorded in Custom 3 of the EndNote library.
  ○ [underlined: Decision codes:]
    ■ R=Retrieve
    ■ E=Exclude
    ■ B=Retrieve for Background
  ○ [underlined: Characteristic codes:] Our first priority is retrieval of systematic reviews, especially those focusing on Veteran or military populations. Our second priority is retrieval of primary studies in Veteran or military populations.For ease of identifying these subsets of publications in the ENL, reviewers should add either or both of the following codes when applicable:
    ■ SR=systematic review
    ■ V=Veteran or military population

### Step 3 Full-text level coding

- Record final decision to include study in review, and any other study characteristics of interest
  ○ Characteristics of interest (recorded in Custom Fields):
    ■ Population: Veteran and/or military, or non-Veteran or non-military
    ■ Risk Article Type: Risk factors, or risk assessment
    ■ Study Design: Systematic Review, clinical trial (randomized or nonrandomized), observational study, or other
  ○ Full-text exclusion codes to be entered into Custom 4:
    ■ 1=Non-English language
    ■ 2=Ineligible country (only including US, UK, Canada, New Zealand, Australia)
    ■ 3=Ineligible outcome
    ■ 4=Study does not evaluate risk factors or assessments
    ■ 5=Ineligible publication type (e.g., letter, editorial, publication available only as abstract, non-systematic review, etc.)
    ■ 6=Ineligible systematic review due to limitations in quality
    ■ 7=Nonsystematic regulatory agency analysis
    ■ 8=Risk factor articles that did not account for major potential confounders
    ■ 9=Primary articles about risk, not a Veteran or military population
- Full-text coding to be completed in the format of a label affixed to each publication in the format shown below. Reviewer 1 will circle relevant characteristics and inclusion decision and list an exclusion code when applicable. Reviewer 2 will verify Reviewer 1's decisions and circle Agree or Disagree. All disagreements will be resolved using a consensus process and consensus decisions recorded.
- Label:
  - Pop: Vet-Mil / Non-Vet-Mil
  - Risk: Risk / Assess / NA
  - Design: SR / CT / Obs / Other
  - Rev1: Include / Exclude – Code: ____
  - Rev2: Agree / Disagree Consensus: _____