# EXCLUDED STUDIES

The following full-text publications were considered for inclusion but failed to meet the criteria for this report.

Exclusion codes:

- 1 = non-English language
- 2 = ineligible country
- 3 = ineligible outcome
- 4 = did not evaluate risk factors or assessments
- 5 = ineligible publication type
- 6 = ineligible systematic review due to limitations in quality
- 7 = ineligible nonsystematic regulatory agency analysis
- 8 = did not account for major potential confounders
- 9 = primary articles about risk, not a Veteran or military population

Excluded Trials | | Exclusion Code
1 | Abe K, Mertz KJ, Powell KE, Hanzlick RL. Characteristics of black and white suicide decedents in Fulton County, Georgia, 1988-2002. Am J Public Health. 2006 Oct;96(10): 1794-8. | 9
2 | Acharya N, Rosen AS, Polzer JP, et al. Duloxetine: meta-analyses of suicidal behaviors and ideation in clinical trials for major depressive disorder. [erratum appears in J Clin Psychopharmacol 27 (1): 57]. J Clin Psychopharmacol. 2006 Dec;26(6):587-94. | 6
3 | Afifi TO, MacMillan H, Cox BJ, Asmundson GJ, Stein MB, Sareen J. Mental health correlates of intimate partner violence in marital relationships in a nationally representative sample of males and females. Journal of Interpersonal Violence. 2009 Aug;24(8): 1398-417. | 9
4 | Ahmadian M, Fata L, Asgharnezhad A, Malakooti K. A comparison of the early maladaptive schemas of suicidal and non-suicidal depressed patients with non-clinical sample. Advances in Cognitive Science. 2008 Win;10(4; 40):98. | 1
5 | Ahs AM, Westerling R. Mortality in relation to employment status during different levels of unemployment. Scand J Public Health. 2006;34(2): 159-67. | 2
6 | Akdeniz F, Karadag F. Does menstrual cycle affect mood disorders? Turk Psikiyatri Dergisi. 2006;17(4):296-304. | 6
7 | Aksoy-Poyraz C, Ozdemir A, Ozmen M, Arikan K, Ozkara C. Electroconvulsive therapy for bipolar depressive and mixed episode with high suicide risk after epilepsy surgery. Epilepsy & Behavior. 2008 Nov;13(4):707-9. | 2
8 | Alexander MJ, Haugland G, Ashenden P, Knight E, Brown I. Coping with thoughts of suicide: techniques used by consumers of mental health services. Psychiatr Serv. 2009 Sep;60(9):1214-21. | 4
9 | Allen JP, Cross G, Swanner J. Suicide in the Army: a review of current information. Mil Med. 2005 Jul;170(7):580-4. | 5
10 | Allmer C, Ventegodt S, Kandel I, Merrick J. Positive effects, side effects and adverse events of clinical holistic medicine. A review of Gerda Boyesen's non-pharmaceutical mind-body medicine (biodynamic body-psychotherapy) at two centres in United Kingdom and Germany. International Journal of Adolescent Medicine and Health. 2009 Jul-Sep;21(3):281-97. | 5
11 | Altamura AC, Mundo E, Bassetti R, et al. Transcultural differences in suicide attempters: analysis on a high-risk population of patients with schizophrenia or schizoaffective disorder. Schizophr Res. 2007 Jan;89(1-3): 140-6. | 3
12 | Ancoli-Israel S, Cooke JR. Prevalence and Comorbidity of Insomnia and Effect on Functioning in Elderly Populations. J Am Geriatr Soc. 2005;53(Suppl. 7):S264-71. | 5
13 | Andersson N, Ledogar RJ. The CIET Aboriginal Youth Resilience Studies: 14 Years of Capacity Building and Methods Development in Canada. Pimatisiwin 2008 Summer;6(2):65-88. | 5
14 | Andrade C, Bhakta SG, Singh NM. Controversy revisited: Selective serotonin reuptake inhibitors in paediatric depression. World J Biol Psychiatry. 2006;7(4):251-60. | 5
15 | Andriessen K, Krysinska K. Can sports events affect suicidal behavior? A review of the literature and implications for prevention. Crisis: The Journal of Crisis Intervention and Suicide Prevention. 2009;30(3): 144-52. | 5
16 | Anestis MD, Joiner TE. Examining the role of emotion in suicidality: negative urgency as an amplifier of the relationship between components of the interpersonal-psychological theory of suicidal behavior and lifetime number of suicide attempts. J Affect Disord. 2011 Mar;129(1-3):261-9. | 9
17 | Angst J, Angst F, Gerber-Werder R, Gamma A. Suicide in 406 Mood-Disorder Patients With and Without Long-Term Medication: A 40 to 44 Years' Follow-Up. Archives of Suicide Research. 2005 Sep;9(3):279-300. | 2
18 | Appleby BS, Duggan PS, Regenberg A, Rabins PV Psychiatric and neuropsychiatric adverse events associated with deep brain stimulation: A meta-analysis of ten years' experience. Mov Disord. 2007 Sep 15;22(12): 1722-8. | 6
19 | Apter A, King RA, Bleich A, Fluck A, Kotler M, Kron S. Fatal and non-fatal suicidal behavior in Israeli adolescent males. Arch Suicide Res. 2008;12(1):20-9. | 2
20 | Apter A, Lipschitz A, Fong R, et al. Evaluation of suicidal thoughts and behaviors in children and adolescents taking paroxetine. J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(1-2):77-90. | 5
21 | Arata CM, Langhinrichsen-Rohling J, Bowers D, O'Brien N. Differential correlates of multi-type maltreatment among urban youth. Child Abuse Negl. 2007 Apr;31(4):393-415. | 3
22 | Arling TA, Yolken RH, Lapidus M, et al. Toxoplasma gondii antibody titers and history of suicide attempts in patients with recurrent mood disorders. J Nerv Ment Dis. 2009 Dec; 197(12):905-8. | 9
23 | Army Suicide Prevention Task Force. Army Health Promotion, Risk Reduction and Suicide Prevention: Report 2010. Washington, D.C.: Department of Defense; 2010. | 5
24 | Arnette NC, Mascaro N, Santana MC, Davis S, Kaslow NJ. Enhancing spiritual well-being among suicidal African American female survivors of intimate partner violence. J Clin Psychol. 2007 Oct;63(10):909-24. | 4
25 | Arnette NC. Prediction of adolescent suicidality: Relative contribution of diagnosis, psychopathy, and impulsivity. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2007;67(12-B):7362. | 9
26 | Asarnow JR, Baraff LJ, Berk M, et al. Pediatric emergency department suicidal patients: two-site evaluation of suicide ideators, single attempters, and repeat attempters. J Am Acad Child Adolesc Psychiatry. 2008 Aug;47(8):958-66. | 9
27 | Asarnow JR, Porta G, Spirito A, et al. Suicide attempts and nonsuicidal self-injury in the treatment of resistant depression in adolescents: findings from the TORDIA study. J Am Acad Child Adolesc Psychiatry. 2011 Aug;50(8):772-81. | 9
28 | Aseltine RH, Jr., Schilling EA, James A, Glanovsky JL, Jacobs D. Age variability in the association between heavy episodic drinking and adolescent suicide attempts: findings from a large-scale, school-based screening program. J Am Acad Child Adolesc Psychiatry. 2009 Mar;48(3):262-70. | 9
29 | Atmaca M, Tezcan E, Parmaksiz S, Saribas M, Ozler S, Ustundag B. Serum ghrelin and cholesterol values in suicide attempters. Neuropsychobiology. 2006;54(1):59-63. | 2
30 | Auquier P, Lancon C, Rouillon F, Lader M, Holmes C. Mortality in schizophrenia. Pharmacoepidemiol Drug Saf. 2006 Dec;15(12):873-9. | 5
31 | Auquier P, Lancon C, Rouillon F, Lader M. Mortality in schizophrenia. Pharmacoepidemiol Drug Saf. 2007 Dec; 16(12): 1308-12. | 5
32 | Auxemery Y, Fidelle G Internet and suicidality: A googling study about mediatic view of a suicidal pact. Annales Medico-Psychologiques. 2010 Sep;168(7):502-7. | 1
33 | Axelson D, Birmaher B, Strober M, et al. Phenomenology of children and adolescents with bipolar spectrum disorders. Arch Gen Psychiatry. 2006 Oct;63(10):1139-48. | 3
34 | Ayalon L, Mackin S, Arean PA, Chen H, McDonel Herr EC. The role of cognitive functioning and distress in suicidal ideation in older adults. J Am Geriatr Soc. 2007 Jul;55(7): 1090-4. | 3
35 | Ayer DW, Jayathilake K, Meltzer HY. The InterSePT suicide scale for prediction of imminent suicidal behaviors. Psychiatry Res. 2008 Oct 30;161(1):87-96. | 2
36 | Ayer L, Althoff R, Ivanova M, et al. Child Behavior Checklist Juvenile Bipolar Disorder (CBCL-JBD) and CBCL Posttraumatic Stress Problems (CBCL-PTSP) scales are measures of a single dysregulatory syndrome. Journal of Child Psychology and Psychiatry. 2009 Oct;50(10): 1291-300. | 9
37 | Ayliffe L, Lagace C, Muldoon P. The use of a mental health triage assessment tool in a busy Canadian tertiary care children's hospital. J Emerg Nurs. 2005;31(2): 161-5. | 5
38 | Baca-Garcia E, Perez-Rodriguez M, Oquendo MA, et al. Estimating risk for suicide attempt: Are we asking the right questions?: Passive suicidal ideation as a marker for suicidal behavior. Journal of Affective Disorders. 2011 Nov;134(1-3):327-32. | 8
39 | Baca-Garcia E, Perez-Rodriguez MM, Diaz Sastre C, Saiz-Ruiz J, de Leon J. Suicidal behavior in schizophrenia and depression: a comparison. Schizophr Res. 2005 Jun 1;75(1):77-81. | 2
40 | Bach-Mizrachi H, Underwood MD, Kassir SA, et al. Neuronal tryptophan hydroxylase mRNA expression in the human dorsal and median raphe nuclei: major depression and suicide. Neuropsychopharmacology. 2006 Apr;31(4):814-24. | 9
41 | Bach-Mizrachi H, Underwood MD, Tin A, Ellis SP, Mann JJ, Arango V Elevated expression of tryptophan hydroxylase-2 mRNA at the neuronal level in the dorsal and median raphe nuclei of depressed suicides. Mol Psychiatry. 2008 May;13(5):507-13, 465. | 9
42 | Baigent MF. Understanding alcohol misuse and comorbid psychiatric disorders. Current Opinion in Psychiatry. 2005 May;18(3):223-8. | 5
43 | Bajbouj M, Merkl A, Schlaepfer TE, et al. Two-year outcome of vagus nerve stimulation in treatment-resistant depression. J Clin Psychopharmacol. 2010 Jun;30(3):273-81. | 2
44 | Bakim B, Karamustafalioglu K, Akpinar A. Suicides and attempted suicides in alcohol and other substance use disorders. Bagimlik Dergisi. 2007 Aug;8(2):91-6. | 1
45 | Bakim B, Karamustafalioglu K, Ogutcen O, Yumrukcal H. Alcohol-Substance Use Disorders in HIV Infection. Bagimlik Dergisi. 2006 Aug;7(2):91-7. | 1
46 | Bakst S, Rabinowitz J, Bromet EJ. Antecedents and patterns of suicide behavior in first-admission psychosis. Schizophr Bull. 2010 Jul;36(4):880-9. | 9
47 | Bakst S, Rabinowitz J, Bromet EJ. Is poor premorbid functioning a risk factor for suicide attempts in first-admission psychosis? Schizophr Res. 2010 Feb;116(2-3):210-6. | 9
48 | Balci Y, Canogullari G, Ulupinar E. Characterization of the gunshot suicides. J Forensic Leg Med. 2007 May; 14(4):203-8. | 2
49 | Baldassano CF Illness course, comorbidity, gender, and suicidality in patients with bipolar disorder. J Clin Psychiatry. 2006;67 Suppl 11:8-11. | 9
50 | Baldessarini RJ, Pompili M, Tondo L. Suicidal risk in antidepressant drug trials. Arch Gen Psychiatry. 2006 Mar;63(3):246-8. | 5
51 | Baldessarini RJ, Tondo L, Davis P, Pompili M, Goodwin FK, Hennen J. Decreased risk of suicides and attempts during long-term lithium treatment: a meta-analytic review. Bipolar Disord. 2006 Oct;8(5 Pt 2):625-39. | 6
52 | Baldwin DS, Reines EH, Guiton C, Weiller E. Escitalopram therapy for major depression and anxiety disorders. Ann Pharmacother. 2007 Oct;41(10):1583-92. | 5
53 | Balestrieri M, Rucci P, Sbrana A, et al. Lifetime rhythmicity and mania as correlates of suicidal ideation and attempts in mood disorders. Compr Psychiatry. 2006 Sep-Oct;47(5):334-41. | 2
54 | Balis T, Postolache TT. Ethnic differences in adolescent suicide in the United States. International Journal of Child Health and Human Development. 2008; 1(3,Spec Iss):281-96. | 5
55 | Ballard ED, Pao M, Horowitz L, Lee LM, Henderson DK, Rosenstein DL. Aftermath of suicide in the hospital: institutional response. Psychosomatics. 2008 Nov-Dec;49(6):461-9. | 5
56 | Balousek S, Plane MB, Fleming M. Prevalence of interpersonal abuse in primary care patients prescribed opioids for chronic pain. J Gen Intern Med. 2007 Sep;22(9): 1268-73. | 9
57 | Balsis S, Cully JA. Comparing depression diagnostic symptoms across younger and older adults. Aging Ment Health. 2008 Nov;12(6):800-6. | 3
58 | Bangs ME, Tauscher-Wisniewski S, Polzer J, et al. Meta-analysis of suicide-related behavior events in patients treated with atomoxetine. Journal of the American Academy of Child & Adolescent Psychiatry. 2008 Feb;47(2):209-18. | 5
59 | Barak Y, Olmer A, Aizenberg D. Antidepressants reduce the risk of suicide among elderly depressed patients. Neuropsychopharmacology. 2006 Jan;31(1):178-81. | 9
60 | Barak Y. The aging of Holocaust survivors: myth and reality concerning suicide. Isr Med Assoc J. 2007 Mar;9(3): 196-8. | 5
61 | Barbe RP, Rubovszky G, Venturini-Andreoli A, Andreoli A. The treatment of borderline personality disorder patients with current suicidal behaviour. Clinical Neuropsychiatry: Journal of Treatment Evaluation. 2005 Sep;2(5):283-91. | 5
62 | Basham C, Denneson LM, Millet L, Shen X, Duckart J, Dobscha SK. Characteristics and VA Health Care Utilization of U. S. Veterans Who Completed Suicide in Oregon Between 2000 and 2005. Suicide Life Threat Behav. 2011 Apr 4;42(3):287-96. | 8
63 | Bauer MS, Wisniewski SR, Kogan JN, Marangell LB, Thase ME, Sachs G Brief report: paroxetine in younger and adult individuals at high risk for suicide. Psychopharmacol Bull. 2006;39(1):31-7. | 3
64 | Baum AL. Suicide in athletes: a review and commentary. Clin Sports Med. 2005 Oct;24(4):853-69, ix. | 5
65 | Beasley CM, Jr., Ball SG, Nilsson ME, et al. Fluoxetine and adult suicidality revisited: an updated meta-analysis using expanded data sources from placebo-controlled trials. J Clin Psychopharmacol. 2007 Dec;27(6):682-6. | 7
66 | Beautrais AL, Fergusson DM, Horwood LJ. Firearms legislation and reductions in firearm-related suicide deaths in New Zealand. Aust N Z J Psychiatry. 2006 Mar;40(3):253-9. | 4
67 | Beautrais AL, Gibb SJ, Fergusson DM, Horwood LJ, Larkin GL. Removing bridge barriers stimulates suicides: an unfortunate natural experiment. Aust N Z J Psychiatry. 2009 Jun;43(6):495-7. | 4
68 | Beghi M, Rosenbaum JF. Risk factors for fatal and nonfatal repetition of suicide attempt: a critical appraisal. Curr Opin Psychiatry. 2010 Jul;23(4):349-55. | 6
69 | Bell GS, Gaitatzis A, Bell CL, Johnson AL, Sander JW. Suicide in people with epilepsy: how great is the risk? Epilepsia. 2009 Aug;50(8): 1933-42. | 6
70 | Benda BB. Gender Differences in Predictors of Suicidal Thoughts and Attempts Among Homeless Veterans that Abuse Substances. Suicide and Life Threatening Behavior. 2005 Feb;35(1): 106-16. | 8
71 | Benham C. The relationship between creativity and psychiatric vulnerability: A meta-analysis of empirical studies. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;65(12-B):6641. | 3
72 | Bennewith O, Nowers M, Gunnell D. Effect of barriers on the Clifton suspension bridge, England, on local patterns of suicide: implications for prevention. Br J Psychiatry. 2007 Mar; 190:266-7. | 4
73 | Berard R, Fong R, Carpenter DJ, Thomason C, Wilkinson C. An international, multicenter, placebo-controlled trial of paroxetine in adolescents with major depressive disorder. J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(1-2):59-75. | 2
74 | Bergen H, Hawton K, Murphy E, et al. Trends in prescribing and self-poisoning in relation to UK regulatory authority warnings against use of SSRI antidepressants in under-18-year-olds. Br J Clin Pharmacol. 2009 Oct;68(4):618-29. | 9
75 | Bergman J, Miodownik C, Palatnik A, Lerner V Efficacy of bupropion XR in treatment-resistant elderly patients: a case series study. Clin Neuropharmacol. 2011 Jan-Feb;34(1): 17-20. | 4
76 | Berlin I, Chen H, Covey LS. Depressive mood, suicide ideation and anxiety in smokers who do and smokers who do not manage to stop smoking after a target quit day. Addiction. 2010 Dec;105(12):2209-16. | 3
77 | Bernert RA, Joiner TE. Sleep disturbances and suicide risk: A review of the literature. Neuropsychiatr Dis Treat. 2007 Dec;3(6):735-43. | 5
78 | Bessant M, King EA, Peveler R. Characteristics of suicides in recent contact with NHS Direct. Psychiatric Bulletin. 2008 Mar;32(3):92-5. | 9
79 | Bhui K, McKenzie K, Rasul F. Rates, risk factors & methods of self harm among minority ethnic groups in the UK: a systematic review. BMC Public Health. 2007;7:336. | 6
80 | Bishop SC, Basch S, Futterweit W. Polycystic ovary syndrome, depression, and affective disorders. Endocr Pract. 2009 Jul-Aug;15(5):475-82. | 6
81 | Black SA, Gallaway M, Bell MR, Ritchie EC. Prevalence and risk factors associated with suicides of Army soldiers 2001-2009. Military Psychology. 2011 Jul;23(4):433-51. | 8
82 | Bocchetta A, Fadda D, Satta G, Del Zompo M, Gessa GL, Cocco P. Long-term lithium treatment and survival from external causes including suicide. Journal of Clinical Psychopharmacology. 2007 Oct;27(5):544-6. | 9
83 | Bodner E, Ben-Artzi E, Kaplan Z. Soldiers who kill themselves: the contribution of dispositional and situational factors. Arch Suicide Res. 2006;10(1):29-43. | 2
84 | Bohnert AS, Roeder K, Ilgen MA. Unintentional overdose and suicide among substance users: A review of overlap and risk factors. Drug and Alcohol Dependence. 2010 Aug;110(3): 183-92. | 6
85 | Boivin JF, Roy E, Haley N, Galbaud du Fort G The health of street youth: a Canadian perspective. Can J Public Health. 2005 Nov-Dec;96(6):432-7. | 5
86 | Bonnewyn A, Shah A, Demyttenaere K. Suicidality and suicide in older people. Reviews in Clinical Gerontology. 2009 Nov;19(4):271-94. | 6
87 | Borges G, Loera CR. Alcohol and drug use in suicidal behaviour. Current Opinion in Psychiatry. 2010 May;23(3): 195-204. | 5
88 | Borschmann R Hogg J, Phillips R, Moran P. Measuring self-harm in adults: A systematic review. Eur Psychiatry. 2011 Jun 20. | 6
89 | Boscarino JA. Posttraumatic stress disorder and mortality among U.S. Army veterans 30 years after military service. Ann Epidemiol. 2006 Apr; 16(4):248-56. | 5
90 | Boscarino JA. The mortality impact of combat stress 30 years after exposure: Implications for prevention, treatment, and research. Figley, Charles R [Ed]. 2007:97-117. | 3
91 | Bossarte RM, Claassen CA, Knox KL. Evaluating evidence of risk for suicide among veterans. Mil Med. 2010 Oct;175(10):703-4. | 5
92 | Bouris A, Guilamo-Ramos V, Pickard A, et al. A systematic review of parental influences on the health and well-being of lesbian, gay, and bisexual youth: time for a new public health research and practice agenda. J Prim Prev. 2010 Dec;31(5-6):273-309. | 6
93 | Bowers L, Banda T, Nijman H. Suicide inside: a systematic review of inpatient suicides. J Nerv Ment Dis. 2010 May;198(5):315-28. | 6
94 | Brady J. The association between alcohol misuse and suicidal behaviour. Alcohol and Alcoholism. 2006 Sep-Oct;41(5):473-8. | 5
95 | Brand BL, Classen CC, McNary SW, Zaveri P. A review of dissociative disorders treatment studies. Journal of Nervous and Mental Disease. 2009 Sep; 197(9):646-54. | 3
96 | Bray RM, Pemberton MR, Lane ME, Hourani LL, Mattiko MJ, Babeu LA. Substance use and mental health trends among U.S. military active duty personnel: key findings from the 2008 DoD Health Behavior Survey. Mil Med. 2010 Jun;175(6):390-9. | 8
97 | Breggin PR. Recent U.S., Canadian, and British Regulatory Agency Actions Concerning Antidepressant-Induced Harm to Self and Others: A Review and Analysis. Ethical Human Psychology and Psychiatry: An International Journal of Critical Inquiry. 2005 Spr;7(1):7-22. | 5
98 | Brenner LA, Homaifar BY, Adler LE, Wolfman JH, Kemp J. Suicidality and veterans with a history of traumatic brain injury: precipitants events, protective factors, and prevention strategies. Rehabil Psychol. 2009 Nov;54(4):390-7. | 3
99 | Brent D, Emslie G, Clarke G, et al. Switching to another SSRI or to venlafaxine with or without cognitive behavioral therapy for adolescents with SSRI-resistant depression: the TORDIA randomized controlled trial. JAMA. 2008;299(8):901-13. | 4
100 | Brent DA, Emslie GJ, Clarke GN, et al. Predictors of spontaneous and systematically assessed suicidal adverse events in the treatment of SSRI-resistant depression in adolescents (TORDIA) study. Am J Psychiatry. 2009 Apr;166(4):418-26. | 4
101 | Brent DA, Greenhill LL, Compton S, et al. The Treatment of Adolescent Suicide Attempters study (TASA): predictors of suicidal events in an open treatment trial. Journal of the American Academy of Child and Adolescent Psychiatry. 2009 Oct;48(10):987-96. | 9
102 | Breslau N, Schultz LR Johnson EO, Peterson EL, Davis GC. Smoking and the Risk of Suicidal Behavior. Archives of General Psychiatry. 2005 Mar;62(3):328-34. | 9
103 | Brewin C, Garnett R, Andrews B. Trauma, identity and mental health in UK military veterans. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2011 Aug;41(8): 1733-40. | 3
104 | Brezo J, Barker ED, Paris J, et al. Childhood trajectories of anxiousness and disruptiveness as predictors of suicide attempts. Arch Pediatr Adolesc Med. 2008 Nov;162(11):1015-21. | 9
105 | Brezo J, Paris J, Barker ED, et al. Natural history of suicidal behaviors in a population-based sample of young adults. Psychol Med. 2007 Nov;37(11):1563-74. | 9
106 | Brezo J, Paris J, Hebert M, Vitaro F, Tremblay R Turecki G Broad and narrow personality traits as markers of one-time and repeated suicide attempts: a population-based study. BMC Psychiatry. 2008;8:15. | 9
107 | Brezo J, Paris J, Tremblay R, Vitaro F, Hebert M, Turecki G Identifying correlates of suicide attempts in suicidal ideators: a population-based study. Psychol Med. 2007 Nov;37(11): 1551-62. | 9
108 | Brezo J, Paris J, Turecki G Personality traits as correlates of suicidal ideation, suicide attempts, and suicide completions: A systematic review. Acta Psychiatrica Scandinavica. 2006 Mar;113(3):180-206. | 6
109 | Bridge JA, Barbe RP, Birmaher B, Kolko DJ, Brent DA. Emergent suicidality in a clinical psychotherapy trial for adolescent depression. Am J Psychiatry. 2005 Nov;162(11):2173-5. | 4
110 | Bridge JA, Goldstein TR Brent DA. Adolescent suicide and suicidal behavior. Journal of Child Psychology and Psychiatry. 2006 Mar-Apr;47(3-4):372-94. | 5
111 | Britton PC, Conner KR. Suicide attempts within 12 months of treatment for substance use disorders. Suicide Life Threat Behav. 2010 Feb;40(1): 14-21. | 9
112 | Brody S, Potterat JJ, Muth SQ, Woodhouse DE. Psychiatric and Characterological Factors Relevant to Excess Mortality in a Long-Term Cohort of Prostitute Women. Journal of Sex & Marital Therapy. 2005;31(2):97-112. | 6
113 | Brower KJ, McCammon RJ, Wojnar M, Ilgen MA, Wojnar J, Valenstein M. Prescription sleeping pills, insomnia, and suicidality in the National Comorbidity Survey Replication. J Clin Psychiatry. 2011 Apr;72(4):515-21. | 9
114 | Brown GR McBride L, Bauer MS, Williford WO, Cooperative Studies Program 430 Study T. Impact of childhood abuse on the course of bipolar disorder: a replication study in U.S. veterans. J Affect Disord. 2005 Dec;89(1-3):57-67. | 4
115 | Bruce ML. Suicide risk and prevention in veteran populations. Ann N Y Acad Sci. 2010 Oct; 1208:98-103. | 5
116 | Bryan CJ, Cukrowicz KC, West CL, Morrow CE. Combat experience and the acquired capability for suicide. J Clin Psychol. 2010 Oct;66(10): 1044-56. | 3
117 | Bryan CJ, Cukrowicz KC. Associations between types of combat violence and the acquired capability for suicide. Suicide Life Threat Behav. 2011 Apr;41(2): 126-36. | 3
118 | Bryan CJ, Johnson LG, David Rudd M, Joiner TE, Jr. Hypomanic symptoms among first-time suicide attempters predict future multiple attempt status. J Clin Psychol. 2008 Apr;64(4):519-30. | 8
119 | Bryan CJ, Morrow CE, Anestis MD, Joiner TE. A preliminary test of the interpersonal-psychological theory of suicidal behavior in a military sample. Personality and Individual Differences. 2010;48(3):347-50. | 3
120 | Burrows S, Laflamme L. Socioeconomic disparities and attempted suicide: state of knowledge and implications for research and prevention. Int J Inj Contr Saf Promot. 2010 Mar; 17(1):23-40. | 6
121 | Bursztein Lipsicas C, Henrik Makinen I. Immigration and suicidality in the young. The Canadian Journal of Psychiatry / La Revue canadienne de psychiatrie. 2010 May;55(5):274-81. | 6
122 | Bushe CJ, Taylor M, Haukka J. Mortality in schizophrenia: a measurable clinical endpoint. J Psychopharmacol. 2010 Nov;24(4 Suppl): 17-25. | 5
123 | Butler T, Allnutt S, Kariminia A, Cain D. Mental health status of Aboriginal and non-Aboriginal Australian prisoners. Aust N Z J Psychiatry. 2007 May;41(5):429-35. | 9
124 | Butterfield MI, Stechuchak KM, Connor KM, et al. Neuroactive Steroids and Suicidality in Posttraumatic Stress Disorder. The American Journal of Psychiatry. 2005 Feb;162(2):380-2. | 8
125 | Cahill K, Stead LF, Lancaster T. Nicotine receptor partial agonists for smoking cessation. Cochrane Database Syst Rev. 2011 (2):CD006103. | 3
126 | Calabrese J, Keck P, Macfadden W, et al. A randomized, double-blind, placebo-controlled trial of quetiapine in the treatment of Bipolar I or II depression. Am J Psychiatry. 2005; 162:1351-60. | 9
127 | Calati R Porcelli S, Giegling I, et al. Catechol-o-methyltransferase gene modulation on suicidal behavior and personality traits: Review, meta-analysis and association study. Journal of Psychiatric Research. 2011 Mar;45(3):309-21. | 6
128 | Capron DW, Cougle JR, Ribeiro JD, Joiner TE, Schmidt NB. An interactive model of anxiety sensitivity relevant to suicide attempt history and future suicidal ideation. J Psychiatr Res. 2011 Nov 4. | 3
129 | Carballo JJ, Currier D, Figueroa AE, et al. Neurobiological underpinnings of suicidal behavior: Integrating data from clinical and biological studies. The European Journal of Psychiatry. 2009 Oct-Dec;23(4):243-59. | 5
130 | Carpenter DJ, Fong R Kraus JE, Davies JT, Moore C, Thase ME. Meta-analysis of efficacy and treatment-emergent suicidality in adults by psychiatric indication and age subgroup following initiation of paroxetine therapy: a complete set of randomized placebo-controlled trials. J Clin Psychiatry. 2011 Feb 22. | 6
131 | Carr A. Depression in young people: description, assessment and evidence-based treatment. Dev Neurorehabil. 2008 Jan-Mar;11(1):3-15. | 5
132 | Carragher N, Mewton L, Slade T, Teesson M. An item response analysis of the DSM-IV criteria for major depression: Findings from the Australian National Survey of Mental Health and Wellbeing. Journal of Affective Disorders. 2011 Apr;130(1-2):92-8. | 3
133 | Catanese AA, John MS, Di Battista J, Clarke DM. Acute cognitive therapy in reducing suicide risk following a presentation to an emergency department. Behaviour Change. 2009 May;26(1): 16-26. | 9
134 | Cauffman E, MacIntosh R. A Rasch Differential Item Functioning Analysis of the Massachusetts Youth Screening Instrument: Identifying Race and Gender Differential Item Functioning Among Juvenile Offenders. Educational and Psychological Measurement. 2006 Jun;66(3):502-21. | 3
135 | Chan J, Draper B, Banerjee S. Deliberate self-harm in older adults: A review of the literature from 1995 to 2004. International Journal of Geriatric Psychiatry. 2007 Aug;22(8):720-32. | 5
136 | Chiesa M, Fonagy P, Gordon J. Community-based psychodynamic treatment program for severe personality disorders: clinical description and naturalistic evaluation. J Psychiatr Pract. 2009 Jan; 15(1): 12-24. | 4
137 | Chioqueta AP, Stiles TC. Psychometric properties of the Beck Scale for Suicide Ideation: a Norwegian study with university students. Nord J Psychiatry. 2006;60(5):400-4. | 2
138 | Chiou PN, Chen YS, Lee YC. Characteristics of adolescent suicide attempters admitted to an acute psychiatric ward in Taiwan. J Chin Med Assoc. 2006 Sep;69(9):428-35. | 2
139 | Church MK, Maurer M, Simons FE, et al. Risk of first-generation H(1)-antihistamines: a GA(2) LEN position paper. Allergy. 2010 Apr;65(4):459-66. | 5
140 | Cipriani A, Barbui C, Geddes JR. Suicide, depression, and antidepressants. BMJ. 2005;330(7488):373-4. | 5
141 | Cohen D. Should the use of selective serotonin reuptake inhibitors in child and adolescent depression be banned? Psychother Psychosom. 2007;76(1):5-14. | 5
142 | Cohen VK. Keeping students alive: mandating on-campus counseling saves suicidal college students' lives and limits liability. Fordham Law Rev. 2007 May;75(6):3081-135. | 4
143 | Colucci E, Martin G. Ethnocultural aspects of suicide in young people: a systematic literature review part 1: Rates and methods of youth suicide. Suicide Life Threat Behav. 2007 Apr;37(2): 197-221. | 6
144 | Colucci E, Martin G. Ethnocultural aspects of suicide in young people: a systematic literature review part 2: Risk factors, precipitating agents, and attitudes toward suicide. Suicide Life Threat Behav. 2007 Apr;37(2):222-37. | 6
145 | Combs H, Romm S. Psychiatric inpatient suicide: A literature review. Primary Psychiatry. 2007 Dec;14(12):67-74. | 6
146 | Conrad AK, Jacoby AM, Jobes DA, et al. A psychometric investigation of the Suicide Status Form II with a psychiatric inpatient sample. Suicide Life Threat Behav. 2009 Jun;39(3):307-20. | 9
147 | Cooper J, Kapur N, Dunning J, Guthrie E, Appleby L, Mackway-Jones K. A clinical tool for assessing risk after self-harm. Ann Emerg Med. 2006 Oct;48(4):459-66. | 9
148 | Cooper J, Kapur N, Mackway-Jones K. A comparison between clinicians' assessment and the Manchester Self-Harm Rule: a cohort study. Emerg Med J. 2007 Oct;24(10):720-1. | 9
149 | Cooper SL, Lezotte D, Jacobellis J, Diguiseppi C. Does availability of mental health resources prevent recurrent suicidal behavior? An ecological analysis. Suicide Life Threat Behav. 2006 Aug;36(4):409-17. | 9
150 | Coric V, Stock EG, Pultz J, Marcus R, Sheehan DV. Sheehan Suicidality Tracking Scale (Sheehan-STS): Preliminary results from a multicenter clinical trial in generalized anxiety disorder. Psychiatry. 2009 Jan;6(1):26-31. | 3
151 | Correa H, Viana MM, Romano-Silva MA, Duval F. Psychoneuroendocrinology and suicidal behaviour. Jornal Brasileiro de Psiquiatria. 2005 Apr-Jun;54(2): 138-44. | 1
152 | Coryell WH. Clinical Assessment of Suicide Risk in Depressive Disorder. CNS Spectrums. 2006 Jun;11(6):455-61. | 5
153 | Cotton SM, Lambert M, Schimmelmann BG, et al. Gender differences in premorbid, entry, treatment, and outcome characteristics in a treated epidemiological sample of 661 patients with first episode psychosis. Schizophr Res. 2009 Oct; 114(1-3): 17-24. | 9
154 | Cox DW, Ghahramanlou-Holloway M, Greene FN, et al. Suicide in the United States Air Force: Risk factors communicated before and at death. J Affect Disord. 2011 Jun 6. | 8
155 | Crawford M, Kuforiji B, Ghosh P. The impact of social context on socio-demographic risk factors for suicide: A synthesis of data from case-control studies. Journal of Epidemiology and Community Health. 2010 Jun;64(6):530-4. | 6
156 | Crawford MJ, Sharpe D, Rutter D, Weaver T. Prevention of suicidal behaviour among army personnel: a qualitative study. J R Army Med Corps. 2009 Sep;155(3):203-7. | 5
157 | Crawford MJ, Thana L, Methuen C, et al. Impact of screening for risk of suicide: randomised controlled trial. Br J Psychiatry. 2011 May;198:379-84. | 9
158 | Crow S, Eisenberg ME, Story M, Neumark-Sztainer D. Are body dissatisfaction, eating disturbance, and body mass index predictors of suicidal behavior in adolescents? A longitudinal study. J Consult Clin Psychol. 2008 Oct;76(5):887-92. | 9
159 | Cutcliffe JR, Koehn CV Hope and interpersonal psychiatric/mental health nursing: a systematic review of the literature--part two. J Psychiatr Ment Health Nurs. 2007;14(2):141-7. | 5
160 | Dahle K-P, Lohner JC, Konrad N. Suicide Prevention in Penal Institutions: Validation and Optimization of a Screening Tool for Early Identification of High-Risk Inmates in Pretrial Detention. The International Journal of Forensic Mental Health. 2005 Spr;4(1):53-62. | 2
161 | Daigle MS, Daniel AE, Dear GE, et al. Preventing suicide in prisons, part II. International comparisons of suicide prevention services in correctional facilities. Crisis. 2007;28(3): 122-30. | 5
162 | Daigle MS, Labelle R, Cote G. Further evidence of the validity of the Suicide Risk Assessment Scale for prisoners. Int J Law Psychiatry. 2006 Sep-Oct;29(5):343-54. | 3
163 | Damm N. Risk and protective factors for suicide among combat veterans with posttraumatic stress disorder. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2007;68(6-B):4127. | 3
164 | Daniel AE. Preventing Suicide in Prison: A Collaborative Responsibility of Administrative, Custodial, and Clinical Staff. Journal of the American Academy of Psychiatry and the Law. 2006;34(2): 165-75. | 5
165 | Darke S, Kaye S, McKetin R, Duflou J. Major physical and psychological harms of methamphetamine use. Drug and Alcohol Review. 2008 May;27(3):253-62. | 5
166 | Davis L, Uezato A, Newell JM, Frazier E. Major depression and comorbid substance use disorders. Curr Opin Psychiatry. 2008 Jan;21(1): 14-8. | 5
167 | Davis LL, Frazier EC, Gaynes BN, et al. Are depressed outpatients with and without a family history of substance use disorder different? A baseline analysis of the STAR*D cohort. J Clin Psychiatry. 2007 Dec;68(12):1931-8. | 9
168 | Daviss W. A review of co-morbid depression in pediatric ADHD: Etiologies, phenomenology, and treatment. Journal of Child and Adolescent Psychopharmacology. 2008 Dec;18(6):565-71. | 5
169 | de Abreu LN, Lafer B, Baca-Garcia E, Oquendo MA. Suicidal ideation and suicide attempts in bipolar disorder type I: An update for the clinician. Revista Brasileira de Psiquiatria. 2009 Sep;31(3):271-80. | 5
170 | De Leo D. The world health organization: Approach to evidence-based suicide prevention. Pompili, Maurizio [Ed]. 2011:55-64. | 5
171 | DeFife JA, Drill R Nakash O, Westen D. Agreement between clinician and patient ratings of adaptive functioning and developmental history. The American Journal of Psychiatry. 2010 Dec; 167(12): 1472-8. | 3
172 | Dejong TM, Overholser JC. Assessment of depression and suicidal actions: agreement between suicide attempters and informant reports. Suicide Life Threat Behav. 2009 Feb;39(1):38-46. | 9
173 | Delgado-Gomez D, Blasco-Fontecilla H, Alegria AA, Legido-Gil T, Artes-Rodriguez A, Baca-Garcia E. Improving the accuracy of suicide attempter classification. Artif Intell Med. 2011 Jul;52(3): 165-8. | 2
174 | Denneson LM, Basham C, Dickinson KC, et al. Suicide risk assessment and content of VA health care contacts before suicide completion by veterans in Oregon. Psychiatr Serv. 2010 Dec;61(12):1192-7. | 4
175 | Department of Defense Task Force on the Prevention of Suicide by Members of the Armed Forces. The Challenge and the Promise: Strengthening the Force, Preventing Suicide and Saving Lives. Washington D.C.: Department of Defense; 2010. | 5
176 | Desai RA, Dausey D, Rosenheck RA. Suicide among discharged psychiatric inpatients in the Department of Veterans Affairs. Mil Med. 2008 Aug; 173(8):721-8. | 3
177 | Didham R, Dovey S, Reith D. Characteristics of general practitioner consultations prior to suicide: a nested case-control study in New Zealand. N Z Med J. 2006; 119(1247):U2358. | 9
178 | Doggrell SA. Fluoxetine--do the benefits outweigh the risks in adolescent major depression? Expert Opinion on Pharmacotherapy. 2005;6(1): 147-50. | 5
179 | Doruk A, Celik C, Ozdemir B, Ozsahin A. Adjustment disorder and life events. Anadolu Psikiyatri Dergisi. 2008 Dec;9(4): 197-202. | 2
180 | Dour HJ, Cha CB, Nock MK. Evidence for an emotion-cognition interaction in the statistical prediction of suicide attempts. Behaviour Research and Therapy. 2011 Apr;49(4):294-8. | 9
181 | Duarte-Velez YM, Bernal G. Suicide behavior among Latino and Latino adolescents: Conceptual and methodological issues. Death Studies. 2007;31(5):435-55. | 5
182 | Dube P, Kurt K, Bair MJ, Theobald D, Williams LS. The p4 screener: evaluation of a brief measure for assessing potential suicide risk in 2 randomized effectiveness trials of primary care and oncology patients. Prim Care Companion J Clin Psychiatry. 2010;12(6). | 9
183 | Dudley M, Goldney R, Hadzi-Pavlovic D. Are adolescents dying by suicide taking SSRI antidepressants? A review of observational studies. Australasian Psychiatry. 2010 Jun;18(3):242-5. | 6
184 | Ebmeier KP. No apparent difference in suicide risk between older and newer antidepressants although older drugs may increase risk of suicide attempt during the first month of treatment. Evid Based Ment Health. 2006 Aug;9(3):82. | 4
185 | Eggleston AM, Calhoun PS, Svikis DS, Tuten M, Chisolm MS, Jones HE. Suicidality, aggression, and other treatment considerations among pregnant, substance-dependent women with posttraumatic stress disorder. Compr Psychiatry. 2009 Sep-Oct;50(5):415-23. | 9
186 | Eliason S. Murder-suicide: A review of the recent literature. Journal of the American Academy of Psychiatry and the Law. 2009 Sep;37(3):371-6. | 6
187 | Emslie G, Kratochvil C, Vitiello B, et al. Treatment for Adolescents with Depression Study (TADS): safety results. J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12): 1440-55. | 9
188 | Emslie GJ, Wagner KD, Kutcher S, et al. Paroxetine treatment in children and adolescents with major depressive disorder: a randomized, multicenter, double-blind, placebo-controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45(6):709-19. | 9
189 | Emslie GJ, Yeung PP, Kunz NR. Long-term, open-label venlafaxine extended-release treatment in children and adolescents with major depressive disorder. CNS Spectr. 2007 Mar;12(3):223-33. | 9
190 | Eneman M, Sabbe B. Hopelessness in patients with schizophrenia. Suffering from and with schizophrenia. Tijdschrift voor Psychiatrie 2006;48(5):373-81. | 1
191 | Evans E, Hawton K, Rodham K, Deeks J. The prevalence of suicidal phenomena in adolescents: a systematic review of population-based studies. Suicide Life Threat Behav. 2005 Jun;35(3):239-50. | 6
192 | Evans E, Hawton K, Rodham K. Suicidal phenomena and abuse in adolescents: A review of epidemiological studies. Child Abuse & Neglect. 2005 Jan;29(1):45-58. | 6
193 | Everly GS, Jr., Flynn BW Principles and practical procedures for acute psychological first aid training for personnel without mental health experience. Int J Emerg Ment Health. 2006 Spring;8(2):93-100. | 5
194 | Fajutrao L, Locklear J, Priaulx J, Heyes A. A systematic review of the evidence of the burden of bipolar disorder in Europe. Clin Pract Epidemiol Ment Health. 2009;5:3. | 4
195 | Fazel S, Cartwright J, Norman-Nott A, Hawton K. Suicide in prisoners: a systematic review of risk factors. J Clin Psychiatry. 2008 Nov;69(11):1721-31. | 6
196 | Fear NT, Wessely S. Young people leaving the UK armed forces at increased risk of suicide. Evid Based Ment Health. 2009 Nov; 12(4): 123. | 5
197 | Fedyszyn IE, Robinson J, Matyas T, Harris MG, Paxton SJ. Temporal pattern of suicide risk in young individuals with early psychosis. Psychiatry Res. 2010 Jan 30;175(1-2):98-103. | 9
198 | Felde AB, Westermeyer J, Thuras P. Co-morbid traumatic brain injury and substance use disorder: childhood predictors and adult correlates. Brain Inj. 2006 Jan;20(1):41-9. | 9
199 | Fergusson D, Doucette S, Glass KC, et al. Association between suicide attempts and selective serotonin reuptake inhibitors: Systematic review of randomised controlled trials. BMJ: British Medical Journal. 2005 Feb;330(7488):396. | 6
200 | Fernandez WG, Hartman R, Olshaker J. Brief interventions to reduce harmful alcohol use among military personnel: lessons learned from the civilian experience. Mil Med. 2006 Jun;171(6):538-43. | 5
201 | Fleischmann A, Bertolote JM, Belfer M, Beautrais A. Completed suicide and psychiatric diagnoses in young people: a critical examination of the evidence. Am J Orthopsychiatry. 2005 Oct;75(4):676-83. | 6
202 | Flood AM, Boyle SH, Calhoun PS, et al. Prospective study of externalizing and internalizing subtypes of posttraumatic stress disorder and their relationship to mortality among Vietnam veterans. Comprehensive Psychiatry. 2010 May-Jun;51(3):236-42. | 3
203 | Florentine JB, Crane C. Suicide prevention by limiting access to methods: A review of theory and practice. Social Science & Medicine. 2010 May;70(10): 1626-32. | 5
204 | Flouri E. Psychological and Sociological Aspects of Parenting and Their Relation to Suicidal Behavior. Archives of Suicide Research. 2005 Dec;9(4):373-83. | 5
205 | Foley DL, Goldston DB, Costello EJ, Angold A. Proximal psychiatric risk factors for suicidality in youth: the Great Smoky Mountains Study. Arch Gen Psychiatry. 2006 Sep;63(9): 1017-24. | 9
206 | Foster EM. Deployment and the citizen soldier: need and resilience. Med Care. 2011 Mar;49(3):301-12. | 3
207 | Foster T. Adverse life events proximal to adult suicide: A synthesis of findings from psychological autopsy studies. Archives of Suicide Research. 2011 Jan;15(1):1-15. | 5
208 | Fountoulakis KN, Gonda X, Siamouli M, Rihmer Z. Psychotherapeutic intervention and suicide risk reduction in bipolar disorder: a review of the evidence. J Affect Disord. 2009 Feb;113(1-2):21-9. | 6
209 | Franko DL, Keel PK. Suicidality in eating disorders: Occurrence, correlates, and clinical implications. Clinical Psychology Review. 2006 Oct;26(6):769-82. | 6
210 | Fraser C, Smith K, Judd F, Humphreys J, Fragar L, Henderson A. Farming and Mental Health Problems and Mental Illness. International Journal of Social Psychiatry. 2005 Dec;51(4):340-9. | 5
211 | Freedenthal S. Assessing the wish to die: A 30-year review of Suicide Intent Scale. Archives of Suicide Research. 2008 Sep;12(4):277-98. | 6
212 | Freeman SA. Suicide risk and psychopharmacology: assessment and management of acute and chronic risk factors. J Clin Psychiatry. 2009 Jul;70(7): 1052-3. | 5
213 | Frei A, Han A, Weiss MG, Dittmann V, Ajdacic-Gross V Use of army weapons and private firearms for suicide and homicide in the region of Basel, Switzerland. Crisis. 2006;27(3): 140-6. | 2
214 | Fremouw W, Tyner EA, Strunk JM, Musick R. Suicidal Adult Assessment Protocol--SAAP. VandeCreek, Leon [Ed]. 2008:179-89. | 5
215 | Friedman B, Heisel MJ, Delavan RL. Psychometric properties of the 15-item geriatric depression scale in functionally impaired, cognitively intact, community-dwelling elderly primary care patients. J Am Geriatr Soc. 2005 Sep;53(9): 1570-6. | 9
216 | Friedman T, Wohl Y, Knobler HY, et al. Increased use of mental health services related to isotretinoin treatment: a 5-year analysis. Eur Neuropsychopharmacol. 2006 Aug;16(6):413-6. | 2
217 | Fung YL, Chan ZC. A systematic review of suicidal behaviour in old age: a gender perspective. J Clin Nurs. 2011 Apr 28. | 6
218 | Gallagher CA, Dobrin A. Facility-level characteristics associated with serious suicide attempts and deaths from suicide in juvenile justice residential facilities. Suicide Life Threat Behav. 2006 Jun;36(3):363-75. | 9
219 | Gallo JJ, Bogner HR, Morales KH, Post EP, Lin JY, Bruce ML. The effect of a primary care practice-based depression intervention on mortality in older adults: a randomized trial.[Summary for patients in Ann Intern Med. 2007 May 15;146(10):I38; PMID: 17502628]. Annals of Internal Medicine. 2007;146(10):689-98. | 4
220 | Galor S, Hentschel U. Analysis of suicidal behaviour in Israeli veterans and terror victims with post-traumatic stress disorder by using the computerised Gottschalk-Gleser scales. Clinical Psychologist. 2009 Nov;13(3):102-10. | 2
221 | Gardner W, Klima J, Chisolm D, et al. Screening, triage, and referral of patients who report suicidal thought during a primary care visit. Pediatrics. 2010 May;125(5):945-52. | 3
222 | Garlow SJ, Rosenberg J, Moore JD, et al. Depression, desperation, and suicidal ideation in college students: results from the American Foundation for Suicide Prevention College Screening Project at Emory University. Depress Anxiety. 2008;25(6):482-8. | 9
223 | Garvey KA, Penn JV, Campbell AL, Esposito-Smythers C, Spirito A. Contracting for safety with patients: Clinical practice and forensic implications. Journal of the American Academy of Psychiatry and the Law. 2009 Sep;37(3):363-70. | 5
224 | Garza MJ, Cramer RJ. The Spanish Reasons for Living Inventory (SRFL-I): Factor Structure and Association with Suicide Risk Among Spanish Speaking Hispanics. Arch Suicide Res. 2011 Oct;15(4):354-71. | 3
225 | Gaynes BN, Rush AJ, Trivedi MH, et al. Major depression symptoms in primary care and psychiatric care settings: a cross-sectional analysis. Ann Fam Med. 2007 Mar-Apr;5(2): 126-34. | 9
226 | Gearing RE, Lizardi D. Religion and suicide. Journal of Religion and Health. 2009 Sep;48(3):332-41. | 6
227 | Geddes JR, Barbui C, Cipriani A. Risk of suicidal behaviour in adults taking antidepressants. BMJ. 2009;339:b3066. | 4
228 | Gentile S. Suicidal mothers. J Inj Violence Res. 2011 Jul;3(2):90-7. | 2
229 | Gibbons RD, Brown CH, Hur K, Marcus SM, Bhaumik DK, Mann JJ. Relationship between antidepressants and suicide attempts: an analysis of the Veterans Health Administration data sets. Am J Psychiatry. 2007 Jul;164(7):1044-9. | 8
230 | Gibbs D. Assessing suicidal cognitions in adolescents: Establishing the reliability and validity of the Suicide Cognitions Scale. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2011;71(10-B):6438. | 9
231 | Giner L, Carballo JJ, Guija JA, et al. Psychological autopsy studies: The role of alcohol use in adolescent and young adult suicides. International Journal of Adolescent Medicine and Health. 2007 Jan-Mar;19(1):99-113. | 6
232 | Glass JE, Ilgen MA, Winters JJ, Murray RL, Perron BE, Chermack ST. Inpatient hospitalization in addiction treatment for patients with a history of suicide attempt: A case of support for treatment performance measures. Journal of Psychoactive Drugs. 2010 Sep;42(3):315-25. | 3
233 | Goeb J, Even C, Nicolas G, Gohier B, Dubas F, Garre J. Psychiatric side effects of interferon-beta in multiple sclerosis. European Psychiatry. 2006 May;21(3): 186-93. | 6
234 | Golden WE, Hermann RC, Jewell M, Brewster C. Development of evidence-based performance measures for bipolar disorder: overview of methodology. J Psychiatr Pract. 2008 May; 14 Suppl 2:18-30. | 5
235 | Goldman-Mellor SJ, Saxton KB, Catalano RC. Economic contraction and mental health: A review of the evidence, 1990-2009. International Journal of Mental Health. 2010 Sum;39(2):6-31. | 6
236 | Goldstein BI, Bukstein OG Comorbid substance use disorders among youth with bipolar disorder: opportunities for early identification and prevention. J Clin Psychiatry. 2010 Mar;71(3):348-58. | 5
237 | Gonda X, Fountoulakis KN, Harro J, et al. The possible contributory role of the S allele of 5-HTTLPR in the emergence of suicidality. J Psychopharmacol. 2010 Sep 13;25(7):857-66. | 5
238 | Goodman WK, Murphy TK, Lazoritz M. Risk of Suicidality During Antidepressant Treatment of Children and Adolescents. Primary Psychiatry. 2006 Jan;13(1):43-50. | 5
239 | Goodman WK, Murphy TK, Storch EA. Risk of adverse behavioral effects with pediatric use of antidepressants. Psychopharmacology. 2007 Mar;191(1):87-96. | 5
240 | Goodyer IM, Dubicka B, Wilkinson P, et al. A randomised controlled trial of cognitive behaviour therapy in adolescents with major depression treated by selective serotonin reuptake inhibitors. The ADAPT trial. Health Technol Assess. 2008 May;12(14):iii-iv, ix-60. | 4
241 | Gournellis R, Lykouras L. Psychotic (Delusional) Major Depression in the Elderly: A Review. Current Psychiatry Reviews. 2006 May;2(2):235-44. | 6
242 | Gradus JL, Qin P, Lincoln AK, et al. Acute stress reaction and completed suicide. Int J Epidemiol. 2010 Dec;39(6): 1478-84. | 2
243 | Gradus JL, Qin P, Lincoln AK, et al. Posttraumatic stress disorder and completed suicide. Am J Epidemiol. 2010 Mar 15;171(6):721-7. | 2
244 | Gradus JL, Qin P, Lincoln AK, Miller M, Lawler E, Lash TL. The association between adjustment disorder diagnosed at psychiatric treatment facilities and completed suicide. Clin Epidemiol. 2010;2:23-8. | 2
245 | Graham J, Banaschewski T, Buitelaar J, et al. European guidelines on managing adverse effects of medication for ADHD. Eur Child Adolesc Psychiatry. 2011 Jan;20(1): 17-37. | 5
246 | Graham P. Review of Assessment scales in child and adolescent psychiatry. European Child & Adolescent Psychiatry. 2007 Oct; 16(7):471. | 5
247 | Grek A. Clinical management of suicidality in the elderly: an opportunity for involvement in the lives of older patients. Can J Psychiatry. 2007 Jun;52(6 Suppl 1):47S-57S. | 6
248 | Greydanus D, Patel D, Pratt H. Suicide risk in adolescents with chronic illness: Implications for primary care and specialty pediatric practice: A review. Developmental Medicine & Child Neurology. 2010 Dec;52(12): 1083-7. | 6
249 | Grisso T. Review of Jail Screening Assessment Tool (JSAT): Guidelines for Mental Health Screening in Jails. Psychiatric Services. 2006 Jul;57(7): 1049-50. | 5
250 | Gulec G, Aksaray G. Assessment of sociodemographic, sociocultural and family traits in young suicide attempters. Yeni Symposium: psikiyatri, noroloji ve davranis bilimleri dergisi. 2006 Jul;44(3): 141-50. | 1
251 | Gunnell D, Eddleston M, Phillips MR, Konradsen F. The global distribution of fatal pesticide self-poisoning: systematic review. BMC Public Health. 2007;7:357. | 2
252 | Gunnell D, Saperia J, Ashby D. Selective serotonin reuptake inhibitors (SSRIs) and suicide in adults: Meta-analysis of drug company data from placebo controlled, randomised controlled trials submitted to the MHRA's safety review. BMJ: British Medical Journal. 2005 Feb;330(7488):385. | 6
253 | Gutierrez PM, Brenner LA, Huggins JA. A preliminary investigation of suicidality in psychiatrically hospitalized veterans with traumatic brain injury. Arch Suicide Res. 2008;12(4):336-43. | 8
254 | Gutierrez PM, Osman A. Getting the best return on your screening investment: An analysis of the Suicidal Ideation Questionnaire and Reynolds Adolescent Depression Scale. School Psychology Review. 2009;38(2):200-17. | 9
255 | Gutierrez PM. Integratively Assessing Risk and Protective Factors for Adolescent Suicide. Suicide and Life Threatening Behavior. 2006 Apr;36(2): 129-35. | 5
256 | Haas AP, Eliason M, Mays VM, et al. Suicide and suicide risk in lesbian, gay, bisexual, and transgender populations: Review and recommendations. Journal of Homosexuality. 2011 Jan;58(1):10-51. | 5
257 | Haffner WH. Veteran suicide. Mil Med. 2010 Oct; 175(10):i | 5
258 | Hall WD, Lucke J. How have the selective serotonin reuptake inhibitor antidepressants affected suicide mortality? Australian and New Zealand Journal of Psychiatry. 2006 Nov;40(11-12):941-50. | 6
259 | Hallahan B, Hibbeln JR, Davis JM, Garland MR. Omega-3 fatty acid supplementation in patients with recurrent self-harm. Single-centre double-blind randomised controlled trial. NA. 2007;190:118-22. | 4
260 | Hammad TA, Laughren T, Racoosin J. Suicidality in pediatric patients treated with antidepressant drugs. Arch Gen Psychiatry. 2006 Mar;63(3):332-9. | 3
261 | Hammad TA, Laughren TP, Racoosin JA. Suicide rates in short-term randomized controlled trials of newer antidepressants. J Clin Psychopharmacol. 2006 Apr;26(2):203-7. | 7
262 | Hammerness PG, Vivas FM, Geller DA. Selective serotonin reuptake inhibitors in pediatric psychopharmacology: a review of the evidence. J Pediatr. 2006 Feb; 148(2): 158-65. | 6
263 | Hamrin V, Scahill L. Selective serotonin reuptake inhibitors for children and adolescents with major depression: current controversies and recommendations. Issues Ment Health Nurs. 2005 May;26(4):433-50. | 5
264 | Han D, Wang EC. Remission from depression: A review of venlafaxine clinical and economic evidence. Pharmacoeconomics. 2005;23(6):567-81. | 5
265 | Harrison-Woolrych M. Varenicline and suicide. Safety data from New Zealand. BMJ. 2009;339:b5654. | 5
266 | Harriss L, Hawton K, Zahl D. Value of measuring suicidal intent in the assessment of people attending hospital following self-poisoning or self-injury. British Journal of Psychiatry. 2005 Jan;186(1):60-6. | 9
267 | Harriss L, Hawton K. Suicidal intent in deliberate self-harm and the risk of suicide: The predictive power of the Suicide Intent Scale. Journal of Affective Disorders. 2005 Jun;86(2-3):225-33. | 9
268 | Hart BG. Cutting: unraveling the mystery behind the marks. AAOHN J. 2007 Apr;55(4): 161-6; quiz 7-8. | 5
269 | Hasley JP, Ghosh B, Huggins J, Bell MR, Adler LE, Shroyer AL. A review of “suicidal intent” within the existing suicide literature. Suicide Life Threat Behav. 2008 Oct;38(5):576-91. | 6
270 | Haukka J, Arffman M, Partonen T, et al. Antidepressant use and mortality in Finland: a register-linkage study from a nationwide cohort. Eur J Clin Pharmacol. 2009 Jul;65(7):715-20. | 2
271 | Haukka J, Tiihonen J, Harkanen T, Lonnqvist J. Association between medication and risk of suicide, attempted suicide and death in nationwide cohort of suicidal patients with schizophrenia. Pharmacoepidemiol Drug Saf. 2008 Jul;17(7):686-96. | 2
272 | Haw C, Harwood D, Hawton K. Dementia and suicidal behavior: A review of the literature. International Psychogeriatrics. 2009 Jun;21(3):440-53. | 6
273 | Haw C, Hawton K, Sutton L, Sinclair J, Deeks J. Schizophrenia and Deliberate Self-Harm: A Systematic Review of Risk Factors. Suicide and Life Threatening Behavior. 2005 Feb;35(1):50-62. | 6
274 | Hawgood J, De Leo D. Anxiety disorders and suicidal behaviour: an update. Curr Opin Psychiatry. 2008 Jan;21(1):51-64. | 6
275 | Hawton K, Harriss L, Casey D, et al. Self-harm in UK armed forces personnel: descriptive and case-control study of general hospital presentations. Br J Psychiatry. 2009 Mar;194(3):266-72. | 9
276 | Hawton K, Sutton L, Haw C, Sinclair J, Deeks JJ. Schizophrenia and suicide: systematic review of risk factors. Br J Psychiatry. 2005 Jul; 187:9-20. | 6
277 | Hawton K. Completed suicide after attempted suicide. BMJ. 2010;341:c3064. | 5
278 | Hays JT, Ebbert JO. Adverse effects and tolerability of medications for the treatment of tobacco use and dependence. Drugs. 2010 Dec 24;70(18):2357-72. | 5
279 | Hazell P. Depression in children and adolescents. Clin Evid (Online). 2009;2009. | 3
280 | Hazell P. Depression in children and adolescents. Clin Evid (Online). 2011;2011. | 6
281 | Heisel MJ, Duberstein PR. Suicide Prevention in Older Adults. Clinical Psychology: Science and Practice. 2005 Fal;12(3):242-59. | 5
282 | Heisel MJ, Links PS, Conn D, van Reekum R Flett GL. Narcissistic personality and vulnerability to late-life suicidality. Am J Geriatr Psychiatry. 2007 Sep;15(9):734-41. | 3
283 | Heisel MJ. Suicide and Its Prevention Among Older Adults. The Canadian Journal of Psychiatry / La Revue canadienne de psychiatrie 2006 Mar;51(3):143-54. | 6
284 | Hennekens CH, Hennekens AR, Hollar D, Casey DE. Schizophrenia and increased risks of cardiovascular disease. Am Heart J. 2005 Dec;150(6):1115-21. | 3
285 | Hennen J, Baldessarini RJ. Suicidal risk during treatment with clozapine: A meta-analysis. Schizophrenia Research. 2005 Mar;73(2-3): 139-45. | 5
286 | Herman SM. Is the SADPERSONS Scale accurate for the veterans affairs population? Psychological Services. 2006 May;3(2): 137-41. | 3
287 | Hernandez JAR, Navarro-Ruiz JM, Hernandez GT, Gonzalez AR. Construction of an attitudinal beliefs questionnaire towards suicidal behaviour. Psicothema. 2005 Nov;17(4):684-90. | 1
288 | Herrell R Henter ID, Mojtabai R, et al. First psychiatric hospitalizations in the US military: the National Collaborative Study of Early Psychosis and Suicide (NCSEPS). Psychol Med. 2006 Oct;36(10): 1405-15. | 3
289 | Hesdorffer DC, Berg AT, Kanner AM. An update on antiepileptic drugs and suicide: are there definitive answers yet? Epilepsy Curr. 2010 Nov; 10(6): 137-45. | 5
290 | Hesdorffer DC, Rauch SL, Tamminga CA. Long-term psychiatric outcomes following traumatic brain injury: a review of the literature. J Head Trauma Rehabil. 2009 Nov-Dec;24(6):452-9. | 6
291 | Hetrick S, Merry S, McKenzie J, Sindahl P, Proctor M. Selective serotonin reuptake inhibitors (SSRIs) for depressive disorders in children and adolescents. Cochrane Database Syst Rev. 2007 (3):CD004851. | 3
292 | Hirsch JK. A review of the literature on rural suicide: Risk and protective factors, incidence, and prevention. Crisis: The Journal of Crisis Intervention and Suicide Prevention. 2006;27(4): 189-99. | 5
293 | Hittner JB. How robust is the Werther effect? A re-examination of the suggestion-imitation model of suicide. Mortality. 2005 Aug; 10(3): 193-200. | 5
294 | Holden RR, DeLisle MM. Factor analysis of the Beck Scale for Suicide Ideation with female suicide attempters. Assessment. 2005 Jun;12(2):231-8. | 9
295 | Holden RR, DeLisle MM. Factor Structure of the Reasons for Attempting Suicide Questionnaire (RASQ) with Suicide Attempters. Journal of Psychopathology and Behavioral Assessment. 2006 Mar;28(1):1-8. | 4
296 | Holi MM, Pelkonen M, Karlsson L, et al. Psychometric properties and clinical utility of the Scale for Suicidal Ideation (SSI) in adolescents. BMC Psychiatry. 2005 Feb;5:8. | 2
297 | Holtmann M, Bolte S, Poustka F [Suicidality in depressive children and adolescents during treatment with selective serotonin reuptake inhibitors. Review and meta-analysis of the available randomised, placebo controlled trials]. Nervenarzt. 2006 Nov;77(11):1332-7. | 1
298 | Hong J, Reed C, Novick D, Haro JM, Aguado J. Clinical and economic consequences of medication non-adherence in the treatment of patients with a manic/mixed episode of bipolar disorder: Results from the European Mania in Bipolar Longitudinal Evaluation of Medication (EMBLEM) Study. Psychiatry Res. 2011 May 14. | 2
299 | Hopwood CJ, Baker KL, Morey LC. Extratest validity of Selected Personality Assessment Inventory scales and indicators in an inpatient substance abuse setting. Journal of Personality Assessment. 2008 Nov-Dec;90(6):574-7. | 9
300 | Hor K, Taylor M. Suicide and schizophrenia: a systematic review of rates and risk factors. J Psychopharmacol. 2010 Nov;24(4 Suppl):81-90. | 6
301 | Hough D, Lewis P. A suicide prevention advisory group at an academic medical center. Mil Med. 2010 May;175(5):347-51. | 5
302 | Huesmann L, Taylor LD. The role of media violence in violent behavior. Annual Review of Public Health. 2006;27:393-415. | 5
303 | Hughes JR. Smoking and suicide: A brief overview. Drug and Alcohol Dependence. 2008 Dec;98(3): 169-78. | 5
304 | Hughes S, Cohen D. A systematic review of long-term studies of drug treated and non-drug treated depression. Journal of Affective Disorders. 2009;118(1-3):9-18. | 3
305 | Humeau M, Papet N, Jaafari N, Gotzamanis L, Lafay N, Senon J. Availability of firearms and risk of suicide: A review of the literature. Annales Medico Psychologiques. 2007 May;165(4):269-75. | 1
306 | Hutchinson JW, Greene JP, Hansen SL. Evaluating active duty risk-taking: military home, education, activity, drugs, sex, suicide, and safety method. Mil Med. 2008 Dec;173(12):1164-7. | 5
307 | Huth-Bocks AC, Kerr DC, Ivey AZ, Kramer AC, King CA. Assessment of psychiatrically hospitalized suicidal adolescents: self-report instruments as predictors of suicidal thoughts and behavior. J Am Acad Child Adolesc Psychiatry. 2007 Mar;46(3):387-95. | 9
308 | Hwang JP, Lee TW, Tsai SJ, et al. Cortical and subcortical abnormalities in late-onset depression with history of suicide attempts investigated with MRI and voxel-based morphometry. J Geriatr Psychiatry Neurol. 2010 Sep;23(3):171-84. | 2
309 | Ide N, Wyder M, Kolves K, De Leo D. Separation as an important risk factor for suicide: A systematic review. Journal of Family Issues. 2010 Dec;31(12): 1689-716. | 6
310 | Ilgen MA, Burnette ML, Conner KR, Czyz E, Murray R, Chermack S. The association between violence and lifetime suicidal thoughts and behaviors in individuals treated for substance use disorders. Addict Behav. 2010 Feb;35(2):111-5. | 9
311 | Ilgen MA, Tiet Q, Finney JW, Harris AH. Recent suicide attempt and the effectiveness of inpatient and outpatient substance use disorder treatment. Alcohol Clin Exp Res. 2005 Sep;29(9): 1664-71. | 4
312 | Ilgen MA, Zivin K, McCammon RJ, Valenstein M. Mental illness, previous suicidality, and access to guns in the United States. Psychiatr Serv. 2008 Feb;59(2): 198-200. | 9
313 | Ilgen MA, Zivin K, McCammon RJ, Valenstein M. Pain and suicidal thoughts, plans and attempts in the United States. Gen Hosp Psychiatry. 2008 Nov-Dec;30(6):521-7. | 9
314 | Ille R, Spona J, Zickl M, et al. “Add-On”-therapy with an individualized preparation consisting of free amino acids for patients with a major depression. European Archives of Psychiatry and Clinical Neuroscience. 2007 Jun;257(4):222-9. | 2
315 | Innamorati M, Pompili M, Amore M, et al. Suicide prevention in late life: Is there sound evidence for practice? In: Pompili M, Tatarelli R eds. Evidence-based practice in suicidology: A source book. Cambridge, MA: Hogrefe Publishing; 2011:211-32. | 6
316 | Inoue K, Tanii H, Abe S, et al. The risk factors of suicide by poisoning among psychiatry department outpatients. J Forensic Leg Med. 2008 Jan;15(1):65-7. | 2
317 | Iorio A, Marchesini E, Awad T, Gluud LL. Antiviral treatment for chronic hepatitis C in patients with human immunodeficiency virus. Cochrane Database Syst Rev. 2010 (1):CD004888. | 4
318 | Irons J. Fluvoxamine in the treatment of anxiety disorders. Neuropsychiatr Dis Treat. 2005 Dec;1(4):289-99. | 5
319 | Jacono J, Jacono B. The use of puppetry for health promotion and suicide prevention among Mi'Kmaq youth. J Holist Nurs. 2008 Mar;26(1):50-5. | 5
320 | Jakupcak M, Cook J, Imel Z, Fontana A, Rosenheck R McFall M. Posttraumatic stress disorder as a risk factor for suicidal ideation in Iraq and Afghanistan War veterans. J Trauma Stress. 2009 Aug;22(4):303-6. | 3
321 | Jakupcak M, Hoerster KD, Varra A, Vannoy S, Felker B, Hunt S. Hopelessness and suicidal ideation in Iraq and Afghanistan War Veterans reporting subthreshold and threshold posttraumatic stress disorder. J Nerv Ment Dis. 2011 Apr;199(4):272-5. | 3
322 | Jakupcak M, Vannoy S, Imel Z, et al. Does PTSD moderate the relationship between social support and suicide risk in Iraq and Afghanistan War Veterans seeking mental health treatment? Depress Anxiety. 2010 Nov;27(11):1001-5. | 3
323 | Jakupcak M, Varra EM. Treating Iraq and Afghanistan war veterans with PTSD who are at high risk for suicide. Cognitive and Behavioral Practice. 2011 Feb;18(1):85-97. | 5
324 | Janet Kuramoto S, Brent DA, Wilcox HC. The impact of parental suicide on child and adolescent offspring. Suicide Life Threat Behav. 2009 Apr;39(2):137-51. | 6
325 | Jayasekera H, Carter G, Clover K. Comparison of the Composite International Diagnostic Interview (CIDI-Auto) with clinical diagnosis in a suicidal population. Archives of Suicide Research. 2011 Jan;15(1):43-55. | 3
326 | Jimenez-Trevino L, Blasco-Fontecilla H, Braquehais MD, Ceverino-Dominguez A, Baca-Garcia E. Endophenotypes and suicide behaviour. Actas Esp Psiquiatr. 2011 Jan;39(1):61-9. | 5
327 | Jobe TH, Harrow M. Long-Term Outcome of Patients With Schizophrenia: A Review. The Canadian Journal of Psychiatry / La Revue canadienne de psychiatrie 2005 Dec;50(14):892-900. | 5
328 | Joe S, Bryant H. Evidence-based suicide prevention screening in schools. Children & Schools. 2007 Oct;29(4):219-27. | 5
329 | Joe S, Niedermeier D. Preventing Suicide: A Neglected Social Work Research Agenda. Br J Soc Work. 2006 Nov 8;38(3):507-30. | 6
330 | Joe S, Niedermeier DM. Social work research on African Americans and suicidal behavior: a systematic 25-year review. Health Soc Work. 2008 Nov;33(4):249-57. | 6
331 | Johansson K, Ekblad S, Lindencrona F, Shahnavaz S. Promoting mental health and preventing mental disorder among refugees in Western countries. The International Journal of Mental Health Promotion. 2009 Feb;11(1):32-44. | 5
332 | Johnson J, Wood AM, Gooding P, Taylor PJ, Tarrier N. Resilience to suicidality: The buffering hypothesis. Clinical Psychology Review. 2011 Jun;31(4):563-91. | 6
333 | Joiner TE, Jr., Brown JS, Wingate LR. The Psychology and Neurobiology of Suicidal Behavior. Annual Review of Psychology. 2005;56:287-314. | 5
334 | Jones G, Gavrilovic JJ, McCabe R Becktas C, Priebe S. Treating suicidal patients in an acute psychiatric day hospital: a challenge to assumptions about risk and overnight care. Journal of Mental Health. 2008;17(4):375-87. | 3
335 | Jones-Fairnie H, Ferroni P, Silburn S, D. L. Suicide in Australian veterinarians. Aust Vet J. 2008;86(4): 114-6. | 4
336 | Jorm AF, Kelly CM, Morgan AJ. Participant distress in psychiatric research: a systematic review. Psychol Med. 2007 Jul;37(7):917-26. | 3
337 | Judd F, Cooper A-M, Fraser C, Davis J. Rural suicide--people or place effects? Australian and New Zealand Journal of Psychiatry. 2006 Mar;40(3):208-16. | 5
338 | Juurlink DN, Mamdani MM, Kopp A, Redelmeier DA. The risk of suicide with selective serotonin reuptake inhibitors in the elderly. Am J Psychiatry. 2006 May;163(5):813-21. | 9
339 | Kaczmarek TL, Hagan MP, Kettler RJ. Screening for Suicide Among Juvenile Delinquents: Reliability and Validity Evidence for the Suicide Screening Inventory (SSI). International Journal of Offender Therapy and Comparative Criminology. 2006 Apr;50(2):204-17. | 3
340 | Kaizar EE, Greenhouse JB, Seltman H, Kelleher K. Do antidepressants cause suicidality in children? A Bayesian meta-analysis. Clin Trials. 2006;3(2):73-90; discussion 1-8. | 7
341 | Kang HK, Bullman TA. Risk of suicide among US veterans after returning from the Iraq or Afghanistan war zones. JAMA: Journal of the American Medical Association. 2008 Aug;300(6):652-3. | 8
342 | Kanner AM. Depression and epilepsy: A review of multiple facets of their close relation. Neurologic Clinics. 2009 Nov;27(4):865-80. | 5
343 | Kao YC, Liu YP. Suicidal Behavior and Insight into Illness Among Patients with Schizophrenia Spectrum Disorders. Psychiatr Q. 2010 Oct 26. | 2
344 | Kaplan MS, Huguet N, McFarland BH, Mandle JA. Factors associated with suicide by firearm among U.S. older adult men. Psychology of Men & Masculinity Mar. 2011 Mar(Pagination):No Pagination Specified. | 3
345 | Kaplan MS, McFarland BH, Huguet N. Characteristics of adult male and female firearm suicide decedents: findings from the National Violent Death Reporting System. Inj Prev. 2009 Oct;15(5):322-7. | 9
346 | Kaplan MS, McFarland BH, Huguet N. Firearm suicide among veterans in the general population: findings from the national violent death reporting system. J Trauma. 2009 Sep;67(3):503-7. | 8
347 | Kapur N, While D, Blatchley N, Bray I, Harrison K. Suicide after leaving the UK armed forces--a cohort study. PLoS Med. 2009 Mar 3;6(3):e26. | 8
348 | Karayal ON, Anway SD, Batzar E, Vanderburg DG. Assessments of suicidality in double-blind, placebo-controlled trials of ziprasidone. J Clin Psychiatry. 2011 Mar;72(3):367-75. | 5
349 | Kasckow J, Montross L, Golshan S, et al. Suicidality in middle aged and older patients with schizophrenia and depressive symptoms: relationship to functioning and Quality of Life. Int J Geriatr Psychiatry. 2007 Dec;22(12): 1223-8. | 3
350 | Kashdan TB, Frueh B, Knapp RG, Hebert R, Magruder KM. Social anxiety disorder in veterans affairs primary care clinics. Behaviour Research and Therapy. 2006 Feb;44(2):233-47. | 3
351 | Kasper S, Montgomery SA, Moller HJ, et al. Longitudinal analysis of the suicidal behaviour risk in short-term placebo-controlled studies of mirtazapine in major depressive disorder. World J Biol Psychiatry. 2010 Feb;11(1):36-44. | 3
352 | Katz LY, Elias B, O'Neil J, et al. Aboriginal suicidal behaviour research: from risk factors to culturally-sensitive interventions. J Can Acad Child Adolesc Psychiatry. 2006 Nov;15(4):159-67. | 5
353 | Kausch O, Rugle L, Rowland DY. Lifetime histories of trauma among pathological gamblers. Am J Addict. 2006 Jan-Feb;15(1):35-43. | 4
354 | Kelly CM, Jorm AF, Kitchener BA, Langlands RL. Development of mental health first aid guidelines for suicidal ideation and behaviour: a Delphi study. BMC Psychiatry. 2008;8:17. | 4
355 | Kene-Allampalli P, Hovey JD, Meyer GJ, Mihura JL. Evaluation of the reliability and validity of two clinician-judgment suicide risk assessment instruments. Crisis. 2010;31(2):76-85. | 9
356 | Kenedi CA, Goforth HW. A Systematic Review of the Psychiatric Side-Effects of Efavirenz. AIDS Behav. 2011 Apr 12. | 6
357 | Kennard BD, Silva SG, Mayes TL, et al. Assessment of safety and long-term outcomes of initial treatment with placebo in TADS. The American Journal of Psychiatry. 2009 Mar;166(3):337-44. | 3
358 | Kennedy A, Cloutier P, Glennie JE, Gray C. Establishing best practice in pediatric emergency mental health: a prospective study examining clinical characteristics. Pediatr Emerg Care. 2009 Jun;25(6):380-6. | 3
359 | Kennedy CH, Cook JH, Poole DR Brunson CL, Jones DE. Review of the first year of an overseas military gambling treatment program. Mil Med. 2005 Aug;170(8):683-7. | 8
360 | Kessing LV, Sondergard L, Kvist K, Andersen PK. Suicide risk in patients treated with lithium. Arch Gen Psychiatry. 2005 Aug;62(8):860-6. | 2
361 | Khan A, Schwartz K. Suicide risk and symptom reduction in patients assigned to placebo in duloxetine and escitalopram clinical trials: Analysis of the FDA summary basis of approval reports. Annals of Clinical Psychiatry. 2007 Mar;19(1):31-6. | 7
362 | Kilbane EJ, Gokbayrak N, Galynker I, Cohen L, Tross S. A review of panic and suicide in bipolar disorder: Does comorbidity increase risk? Journal of Affective Disorders. 2009 May;115(1-2):1-10. | 6
363 | Kim YA, Bogner HR, Brown GK, Gallo JJ. Chronic medical conditions and wishes to die among older primary care patients. Int J Psychiatry Med. 2006;36(2): 183-98. | 3
364 | Kim YS, Leventhal B. Bullying and suicide. A review. Int J Adolesc Med Health. 2008 Apr-Jun;20(2): 133-54. | 6
365 | King CA, Klaus N, Kramer A, Venkataraman S, Quinlan P, Gillespie B. The Youth-Nominated Support Team-Version II for suicidal adolescents: A randomized controlled intervention trial. J Consult Clin Psychol. 2009 Oct;77(5):880-93. | 4
366 | King CA, Kramer A, Preuss L, Kerr DC, Weisse L, Venkataraman S. Youth-Nominated Support Team for Suicidal Adolescents (Version 1): a randomized controlled trial. J Consult Clin Psychol. 2006 Feb;74(1): 199-206. | 4
367 | King CA, Merchant CR. Social and interpersonal factors relating to adolescent suicidality: A review of the literature. Archives of Suicide Research. 2008;12(3):181-96. | 6
368 | Kirsch I. Medication and suggestion in the treatment of depression. Contemporary Hypnosis. 2005;22(2):59-66. | 5
369 | Kleespies PM, AhnAllen CG, Knight JA, et al. A study of self-injurious and suicidal behavior in a veteran population. Psychological Services. 2011 Aug;8(3):236-50. | 3
370 | Klein DF. The flawed basis for FDA post-marketing safety decisions: the example of antidepressants and children. Neuropsychopharmacology. 2006 Apr;31(4):689-99. | 5
371 | Klomek AB, Sourander A, Gould M. The association of suicide and bullying in childhood to young adulthood: A review of cross-sectional and longitudinal research findings. The Canadian Journal of Psychiatry / La Revue canadienne de psychiatrie 2010 May;55(5):282-8. | 6
372 | Klonsky E, May A. Rethinking impulsivity in suicide. Suicide and Life-Threatening Behavior. 2010 Dec;40(6):612-9. | 9
373 | Kodaka M, Postuvan V, Inagaki M, Yamada M. A systematic review of scales that measure attitudes toward suicide. Int J Soc Psychiatry. 2010 Apr 8. | 4
374 | Koenig HG. Research on religion, spirituality, and mental health: a review. Can J Psychiatry. 2009 May;54(5):283-91. | 5
375 | Koerts J, Leenders K, Koning M, Bouma A, van Beilen M. The assessment of depression in Parkinson's disease. European Journal of Neurology. 2008 May;15(5):487-92. | 3
376 | Kohli MA, Salyakina D, Pfennig A, et al. Association of genetic variants in the neurotrophic receptor-encoding gene NTRK2 and a lifetime history of suicide attempts in depressed patients. Arch Gen Psychiatry. 2010 Apr;67(4):348-59. | 2
377 | Kolla NJ, Eisenberg H, Links PS. Epidemiology, risk factors, and psychopharmacological management of suicidal behavior in borderline personality disorder. Archives of Suicide Research. 2008 Jan;12(1):1-19. | 6
378 | Konrad N, Daigle MS, Daniel AE, et al. Preventing suicide in prisons, part I. Recommendations from the International Association for Suicide Prevention Task Force on Suicide in Prisons. Crisis. 2007;28(3):113-21. | 5
379 | Kooyman I, Dean K, Harvey S, Walsh E. Outcomes of public concern in schizophrenia. Br J Psychiatry Suppl. 2007 Aug;50:s29-36. | 5
380 | Kostenuik M, Ratnapalan M. Approach to adolescent suicide prevention. Can Fam Physician. 2010 Aug;56(8):755-60. | 5
381 | Koukopoulos A, Albert MJ, Sani G, Koukopoulos AE, Girardi P. Mixed depressive states: Nosologic and therapeutic issues. International Review of Psychiatry. 2005 Feb;17(1):21-37. | 5
382 | Kovacic Z, Henigsberg N, Pivac N, Nedic G, Borovecki A. Platelet serotonin concentration and suicidal behavior in combat related posttraumatic stress disorder. Prog Neuropsychopharmacol Biol Psychiatry. 2008 Feb 15;32(2):544-51. | 2
383 | Kratochvil CJ, Vitiello B, Walkup J, et al. Selective serotonin reuptake inhibitors in pediatric depression: is the balance between benefits and risks favorable? J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(1-2):11-24. | 7
384 | Krause JS, Reed KS, McArdle JJ. Factor structure and predictive validity of somatic and nonsomatic symptoms from the patient health questionnaire-9: a longitudinal study after spinal cord injury. Arch Phys Med Rehabil. 2010 Aug;91(8): 1218-24. | 4
385 | Krishnan K. Psychiatric and Medical Comorbidities of Bipolar Disorder. Psychosomatic Medicine. 2005 Jan-Feb;67(1):1-8. | 5
386 | Krishnan P, Hawranik P. Diagnosis and management of geriatric insomnia: a guide for nurse practitioners. J Am Acad Nurse Pract. 2008 Dec;20(12):590-9. | 5
387 | Krysinska K, De Leo D. Suicide on railway networks: Epidemiology, risk factors and prevention. Australian and New Zealand Journal of Psychiatry. 2008 Sep;42(9):763-71. | 6
388 | Krysinska K, Heller TS, De Leo D. Suicide and deliberate self-harm in personality disorders. Current Opinion in Psychiatry. 2006 Jan;19(1):95-101. | 6
389 | Krysinska K, Lester D. Post-traumatic stress disorder and suicide risk: a systematic review. Arch Suicide Res. 2010;14(1):1-23. | 5
390 | Krysinska K, Martin G The struggle to prevent and evaluate: Application of population attributable risk and preventive fraction to suicide prevention research. Suicide and Life Threatening Behavior. 2009 Oct;39(5):548-57. | 5
391 | Kryzhanovskaya LA, Robertson-Plouch CK, Xu W, Carlson JL, Merida KM, Dittmann RW. The safety of olanzapine in adolescents with schizophrenia or bipolar I disorder: a pooled analysis of 4 clinical trials. J Clin Psychiatry. 2009 Feb;70(2):247-58. | 5
392 | Ku YC, Tsai YF, Lin YC, Lin YP. Suicide experiences among institutionalized older veterans in Taiwan. Gerontologist. 2009 Dec;49(6):746-54. | 2
393 | Kukla L, Hruba D, Tyrlik M. [Suicidal attempts within the set of young adult parents of children observed in ELSPAC study]. Cas Lek Cesk 2008;147(10):527-34. | 1
394 | Kumar S, Malone D. Panic disorder. Clin Evid (Online). 2008;2008. | 3
395 | Kuritarne SI. [Features of borderline suicidality. Review of the literature]. Psychiatr Hung. 2008;23(1):22-33. | 1
396 | Kutcher S, Gardner DM. Use of selective serotonin reuptake inhibitors and youth suicide: Making sense from a confusing story. Current Opinion in Psychiatry. 2008 Jan;21(1):65-9. | 5
397 | Lake CR. How academic psychiatry can better prepare students for their future patients. Part I: the failure to recognize depression and risk for suicide in primary care; problem identification, responsibility, and solutions. Behav Med. 2008 Fall;34(3):95-100. | 5
398 | Lake CR. How academic psychiatry can better prepare students for their future patients. Part II: a course in ultra-brief initial diagnostic screening suitable for future primary care physicians. Behav Med. 2008 Fall;34(3):101-16. | 4
399 | Lakeman R FitzGerald M. How people live with or get over being suicidal: a review of qualitative studies. J Adv Nurs. 2008 Oct;64(2):114-26. | 4
400 | Langhinrichsen-Rohling J, Friend J, Powell A. Adolescent suicide, gender, and culture: A rate and risk factor analysis. Aggression and Violent Behavior. 2009 Sep-Oct;14(5):402-14. | 5
401 | Langhinrichsen-Rohling J, Snarr JD, Slep AM, Heyman RE, Foran HM. Risk for suicidal ideation in the U.S. Air Force: An ecological perspective. Journal of Consulting and Clinical Psychology. 2011 Oct;79(5):600-12. | 3
402 | Lapierre S, Dube M, Bouffard L, Alain M. Addressing suicidal ideations through the realization of meaningful personal goals. Crisis. 2007;28(1): 16-25. | 3
403 | Large M, Ryan C, Nielssen O. The validity and utility of risk assessment for inpatient suicide. Australas Psychiatry. 2011 Dec;19(6):507-12. | 5
404 | Large M, Smith G, Nielssen O. The epidemiology of homicide followed by suicide: a systematic and quantitative review. Suicide Life Threat Behav. 2009 Jun;39(3):294-306. | 4
405 | Large MM, Nielssen OB, Lackersteen SM. Did the introduction of ‘dangerousness’ and ‘risk of harm’ criteria in mental health laws increase the incidence of suicide in the United States of America? Soc Psychiatry Psychiatr Epidemiol. 2009 Aug;44(8):614-21. | 5
406 | Large MM, Nielssen OB. Suicide in Australia: meta-analysis of rates and methods of suicide between 1988 and 2007. Med J Aust. 2010 Apr 19;192(8):432-7. | 4
407 | LeGris J, van Reekum R. The Neuropsychological Correlates of Borderline Personality Disorder and Suicidal Behaviour. The Canadian Journal of Psychiatry / La Revue canadienne de psychiatrie. 2006 Mar;51(3):131-42. | 6
408 | Lemaire CM, Graham DP. Factors associated with suicidal ideation in OEF/OIF veterans. J Affect Disord. 2011 Apr;130(1-2):231-8. | 3
409 | Lemon DD. Killing me softly: A meta-analysis examining risk factors associated with suicide among young African American males. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009;69(10-B):6420. | 6
410 | Leon AC, Solomon DA, Li C, et al. Antidepressants and risks of suicide and suicide attempts: a 27-year observational study. Journal of Clinical Psychiatry. 2011;72(5):580-6. | 9
411 | Lester D, McSwain S, Gunn JF, 3rd. A test of the validity of the IS PATH WARM warning signs for suicide. Psychol Rep. 2011 Apr;108(2):402-4. | 9
412 | Lester D. Resources and Tactics for Preventing Suicide. Clinical Neuropsychiatry: Journal of Treatment Evaluation. 2005 Feb;2(1):32-6. | 4
413 | Lester D. Suicide and Islam. Archives of Suicide Research. 2006;10(1):77-97. | 5
414 | Levinson DF. The genetics of depression: a review. Biol Psychiatry. 2006 Jul 15;60(2):84-92. | 5
415 | Lewis MD, Hibbeln JR, Johnson JE, Lin YH, Hyun DY, Loewke JD. Suicide deaths of active-duty US military and omega-3 fatty-acid status: a case-control comparison. J Clin Psychiatry. 2011 Aug 23. | 8
416 | Li D, Duan Y, He L. Association study of serotonin 2A receptor (5-HT2A) gene with schizophrenia and suicidal behavior using systematic meta-analysis. Biochem Biophys Res Commun. 2006 Feb 17;340(3): 1006-15. | 6
417 | Li D, He L. Meta-analysis supports association between serotonin transporter (5-HTT) and suicidal behavior. Mol Psychiatry. 2007 Jan;12(1):47-54. | 6
418 | Li Z, Page A, Martin G, Taylor R. Attributable risk of psychiatric and socio-economic factors for suicide from individual-level, population-based studies: a systematic review. Soc Sci Med. 2011 Feb;72(4):608-16. | 6
419 | Licinio J, Wong M-L. Depression, antidepressants and suicidality: a critical appraisal. Nat Rev Drug Discov. 2005;4(2):165-71. | 5
420 | Lindahl V, Pearson JL, Colpe L. Prevalence of suicidality during pregnancy and the postpartum. Archives of Women's Mental Health. 2005;8(2):77-87. | 6
421 | Links PS, Eynan R, Heisel MJ, et al. Affective instability and suicidal ideation and behavior in patients with borderline personality disorder. Journal of Personality Disorders. 2007 Feb;21(1):72-86. | 3
422 | Links PS, Hoffman B. Preventing suicidal behaviour in a general hospital psychiatric service: priorities for programming. Can J Psychiatry. 2005 Jul;50(8):490-6. | 6
423 | Liu X, Buysse DJ. Sleep and youth suicidal behavior: A neglected field. Current Opinion in Psychiatry. 2006 May;19(3):288-93. | 5
424 | Lizardi D, Dervic K, Grunebaum MF, Burke AK, Mann J, Oquendo MA. The role of moral objections to suicide in the assessment of suicidal patients. Journal of Psychiatric Research. 2008 Aug;42(10):815-21. | 9
425 | Lizardi D, Gearing R. Religion and suicide: Buddhism, Native American and African religions, atheism, and agnosticism. Journal of Religion and Health. 2010 Sep;49(3):377-84. | 6
426 | Lizardi D, Stanley B. Treatment engagement: A neglected aspect in the psychiatric care of suicidal patients. Psychiatric Services. 2010 Dec;61(12):1183-91. | 6
427 | Long CG, Fulton B, Dolley O, Hollin CR. Dealing with Feelings: the effectiveness of cognitive behavioural group treatment for women in secure settings. Behav Cogn Psychother. 2011 Mar;39(2):243-7. | 4
428 | Lopez-Morinigo JD, Ramos-Rios R, David AS, Dutta R. Insight in schizophrenia and risk of suicide: a systematic update. Compr Psychiatry. 2011 Aug 5. | 6
429 | Ludwig J, Marcotte DE, Norberg K. Anti-depressants and suicide. J Health Econ. 2009 May;28(3):659-76. | 2
430 | Luxton DD, Greenburg D, Ryan J, Niven A, Wheeler G, Mysliwiec V Prevalence and impact of short sleep duration in redeployed OIF soldiers. Sleep. 2011 Sep;34(9):1189-95. | 3
431 | Lynch MA, Howard PB, El-Mallakh P, Matthews JM. Assessment and management of hospitalized suicidal patients. J Psychosoc Nurs Ment Health Serv. 2008 Jul;46(7):45-52. | 5
432 | Lyness JM, Heo M, Datto CJ, et al. Outcomes of minor and subsyndromal depression among elderly patients in primary care settings. Ann Intern Med. 2006 Apr 4; 144(7):496-504. | 3
433 | MacNeil MS. An epidemiologic study of Aboriginal adolescent risk in Canada: The meaning of suicide. Journal of Child and Adolescent Psychiatric Nursing. 2008 Feb;21(1):3-12. | 5
434 | Madhusoodanan S, Ibrahim FA, Malik A. Primary prevention in geriatric psychiatry. Annals of Clinical Psychiatry. 2010 Nov;22(4):249-61. | 5
435 | Magnusson PK, Rasmussen F, Lawlor DA, Tynelius P, Gunnell D. Association of body mass index with suicide mortality: a prospective cohort study of more than one million men. Am J Epidemiol. 2006 Jan 1;163(1):1-8. | 2
436 | Maharaj RG, Nunes P, Renwick S. Health risk behaviours among adolescents in the English-speaking Caribbean: A review. Child and Adolescent Psychiatry and Mental Health. 2009 Mar;3:10. | 2
437 | Mak A. A short review on the diagnostic issues of bipolar spectrum disorders in clinically depressed patients--bipolar II disorder. Hong Kong Journal of Psychiatry. 2007; 17(4): 139-44. | 5
438 | Malmberg, Lena, Fenton, Mark, Rathbone, John. Individual psychodynamic psychotherapy and psychoanalysis for schizophrenia and severe mental illness [Systematic Review]. Cochrane Database of Systematic Reviews. 2010 (3). | 3
439 | Mann J, Currier D. A Review of Prospective Studies of Biologic Predictors of Suicidal Behavior in Mood Disorders. Archives of Suicide Research. 2007;11(1):3-16. | 5
440 | Mann J, Currier D. Evidence-based suicide prevention strategies: An overview. Pompili, Maurizio [Ed]. 2011:67-87. | 5
441 | Manna M. Effectiveness of formal observation in inpatient psychiatry in preventing adverse outcomes: The state of the science. Journal of Psychiatric and Mental Health Nursing. 2010 Apr;17(3):268-73. | 6
442 | Manor I, Gutnik I, Ben-Dor DH, et al. Possible association between attention deficit hyperactivity disorder and attempted suicide in adolescents - a pilot study. Eur Psychiatry. 2010 Apr;25(3): 146-50. | 2
443 | Manthorpe J, Iliffe S. Social work with older people--Reducing suicide risk: A critical review of practice and prevention. British Journal of Social Work. 2011 Jan;41(1):131-47. | 5
444 | Manthorpe J, Iliffe S. Suicide in later life: public health and practitioner perspectives. Int J Geriatr Psychiatry. 2010 Dec;25(12): 1230-8. | 5
445 | Marangell LB, Bauer MS, Dennehy EB, et al. Prospective predictors of suicide and suicide attempts in 1,556 patients with bipolar disorders followed for up to 2 years. Bipolar Disord. 2006 Oct;8(5 Pt 2):566-75. | 9
446 | March J, Silva S, Vitiello B, Team T. The Treatment for Adolescents with Depression Study (TADS): methods and message at 12 weeks. Journal of the American Academy of Child and Adolescent Psychiatry. 2006 Dec;45(12):1393-403. | 9
447 | March JS, Klee BJ, Kremer CM. Treatment benefit and the risk of suicidality in multicenter, randomized, controlled trials of sertraline in children and adolescents. J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(1-2):91-102. | 7
448 | March JS, Silva S, Petrycki S, et al. The Treatment for Adolescents With Depression Study (TADS): long-term effectiveness and safety outcomes. Arch Gen Psychiatry. 2007 Oct;64(10):1132-43. | 9
449 | Marqueling AL, Zane LT Depression and suicidal behavior in acne patients treated with isotretinoin: a systematic review. Semin Cutan Med Surg. 2005 Jun;24(2):92-102. | 6
450 | Marqueling AL, Zane LT. Depression and suicidal behavior in acne patients treated with isotretinoin: a systematic review. Semin Cutan Med Surg. 2007 Dec;26(4):210-20. | 6
451 | Marshall BD, Werb D. Health outcomes associated with methamphetamine use among young people: a systematic review. Addiction. 2010 Jun;105(6):991-1002. | 4
452 | Martin SL, Macy RJ, Sullivan K, Magee ML. Pregnancy-associated violent deaths: the role of intimate partner violence. Trauma Violence Abuse. 2007 Apr;8(2): 135-48. | 6
453 | Maslov B, Marcinko D, Milicevic R, Babic D, Dordevic V, Jakovljevic M. Metabolic syndrome, anxiety, depression and suicidal tendencies in post-traumatic stress disorder and schizophrenic patients. Coll Antropol. 2009 Dec;33 Suppl 2:7-10. | 2
454 | Maughan B, Iervolino AC, Collishaw S. Time trends in child and adolescent mental disorders. Current Opinion in Psychiatry. 2005 Jul;18(4):381-5. | 5
455 | McAuliffe N, Perry L. Making it safer: a health centre's strategy for suicide prevention. Psychiatr Q. 2007 Dec;78(4):295-307. | 3
456 | McCarthy JF, Valenstein M, Kim HM, Ilgen M, Zivin K, Blow FC. Suicide mortality among patients receiving care in the veterans health administration health system. American journal of epidemiology. 2009 Apr 15;169(8):1033-8. | 8
457 | McCartney G, Thomas S, Thomson H, et al. The health and socioeconomic impacts of major multi-sport events: systematic review (1978-2008). BMJ. 2010;340:c2369. | 4
458 | McElroy SL, Kotwal R, Kaneria R, Keck PE, Jr. Antidepressants and suicidal behavior in bipolar disorder. Bipolar Disorders. 2006 Oct;8(5 pt 2):596-617. | 6
459 | McMillan D, Gilbody S, Beresford E, Neilly L. Can we predict suicide and non-fatal self-harm with the Beck Hopelessness Scale? A meta-analysis. Psychol Med. 2007 Jun;37(6):769-78. | 6
460 | Mee S, Bunney BG, Reist C, Potkin SG, Bunney WE. Psychological pain: a review of evidence. J Psychiatr Res. 2006 Dec;40(8):680-90. | 5
461 | Melle I, Johannessen JO, Friis S, et al. Course and predictors of suicidality over the first two years of treatment in first-episode schizophrenia spectrum psychosis. Arch Suicide Res. 2010 Apr; 14(2): 158-70. | 2
462 | Merikangas KR Jin R He JP, et al. Prevalence and correlates of bipolar spectrum disorder in the world mental health survey initiative. Arch Gen Psychiatry. 2011 Mar;68(3):241-51. | 2
463 | Merrick J, Merrick E, Lunsky Y, Kandel I. Review of suicidality in persons with intellectual disability. Israel Journal of Psychiatry and Related Sciences. 2006;43(4):258-64. | 5
464 | Michel PO, Lundin T, Larsson G Suicide rate among former Swedish peacekeeping personnel. Mil Med. 2007 Mar;172(3):278-82. | 2
465 | Miller EJ, Chung H. A literature review of studies of depression and treatment outcomes among U.S. College students since 1990. Psychiatr Serv. 2009 Sep;60(9): 1257-60. | 3
466 | Miller M, Barber C, Azrael D, Calle EE, Lawler E, Mukamal KJ. Suicide among US veterans: A prospective study of 500,000 middle-aged and elderly men. Am J Epidemiol. 2009 Aug 15;170(4):494-500. | 8
467 | Miller PG, Coomber K, Staiger P, Zinkiewicz L, Toumbourou JW. Review of rural and regional alcohol research in Australia. Aust J Rural Health. 2010 Jun;18(3):110-7. | 3
468 | Mills JF, Green K, Reddon JR. An evaluation of the Psychache Scale on an offender population. Suicide Life Threat Behav. 2005 Oct;35(5):570-80. | 9
469 | Mills JF, Kroner DG Predicting suicidal ideation with the Depression Hopelessness and Suicide Screening Form (DHS). Journal of Offender Rehabilitation. 2008;47(1-2):74-100. | 9
470 | Mills PD, Neily J, Luan D, Osborne A, Howard K. Actions and implementation strategies to reduce suicidal events in the Veterans Health Administration. Jt Comm J Qual Patient Saf. 2006 Mar;32(3):130-41. | 3
471 | Mills PD, Watts BV, Miller S, et al. A checklist to identify inpatient suicide hazards in veterans affairs hospitals. Jt Comm J Qual Patient Saf. 2010 Feb;36(2):87-93. | 3
472 | Milner A, De Leo D. Who seeks treatment where? Suicidal behaviors and health care: evidence from a community survey. J Nerv Ment Dis. 2010 Jun;198(6):412-9. | 9
473 | Mironova P, Rhodes AE, Bethell JM, et al. Childhood physical abuse and suicide-related behavior: A systematic review. Vulnerable Children and Youth Studies. 2011 Mar;6(1):1-7. | 6
474 | Moller HJ, Baldwin DS, Goodwin G, et al. Do SSRIs or antidepressants in general increase suicidality? WPA Section on Pharmacopsychiatry: consensus statement. Eur Arch Psychiatry Clin Neurosci. 2008 Aug;258 Suppl 3:3-23. | 6
475 | Moller HJ. Evidence for beneficial effects of antidepressants on suicidality in depressive patients: a systematic review. Eur Arch Psychiatry Clin Neurosci. 2006 Sep;256(6):329-43. | 5
476 | Moller HJ. Is there evidence for negative effects of antidepressants on suicidality in depressive patients? A systematic review. Eur Arch Psychiatry Clin Neurosci. 2006 Dec;256(8):476-96. | 5
477 | Montross LP, Zisook S, Kasckow J. Suicide Among Patients with Schizophrenia: A Consideration of Risk and Protective Factors. Annals of Clinical Psychiatry. 2005 Jul-Sep;17(3): 173-82. | 5
478 | Moreira-Almeida A, Neto FL, Koenig HG. Religiousness and mental health: a review. Rev Bras Psiquiatr. 2006 Sep;28(3):242-50. | 5
479 | Morey LC, Hopwood CJ, Gunderson JG, et al. Comparison of alternative models for personality disorders. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2007 Jul;37(7):983-94. | 9
480 | Morrison R, O'Connor RC. A systematic review of the relationship between rumination and suicidality. Suicide Life Threat Behav. 2008 Oct;38(5):523-38. | 6
481 | Mortimer AM, Singh P, Shepherd CJ, Puthiryackal J. Clozapine for treatment-resistant schizophrenia: National Institute of Clinical Excellence (NICE) guidance in the real world. Clin Schizophr Relat Psychoses. 2010 Apr;4(1):49-55. | 3
482 | Moscicki EK, West JC, Rae DS, Rubio-Stipec M, Wilk JE, Regier DA. Suicidality is associated with medication access problems in publicly insured psychiatric patients. The Journal of clinical psychiatry. 2010 Dec;71(12):1657-63. | 3
483 | Mosholder AD, Willy M. Suicidal adverse events in pediatric randomized, controlled clinical trials of antidepressant drugs are associated with active drug treatment: a meta-analysis. J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(1-2):25-32. | 7
484 | Mouly S, Mahe I, Champion K, et al. Graphology for the diagnosis of suicide attempts: a blind proof of principle controlled study. Int J Clin Pract. 2007 Mar;61(3):411-5. | 2
485 | Mrnak-Meyer J, Tate SR Tripp JC, Worley MJ, Jajodia A, McQuaid JR. Predictors of suicide-related hospitalization among U.S. veterans receiving treatment for comorbid depression and substance dependence: who is the riskiest of the risky? Suicide Life Threat Behav. 2011 Oct;41(5):532-42. | 3
486 | Muehlenkamp JJ, Cowles ML, Gutierrez PM. Validity of the Self-Harm Behavior Questionnaire with diverse adolescents. Journal of Psychopathology and Behavioral Assessment. 2010 Jun;32(2):236-45. | 9
487 | Muehlenkamp JJ, Gutierrez PM, Osman A, Barrios FX. Validation of the Positive and Negative Suicide Ideation (PANSI) Inventory in a Diverse Sample of Young Adults. Journal of Clinical Psychology. 2005 Apr;61(4):431-45. | 4
488 | Mulder RT, Joyce PR, Frampton CM, Luty SE. Antidepressant treatment is associated with a reduction in suicidal ideation and suicide attempts. Acta Psychiatr Scand. 2008 Aug; 118(2): 116-22. | 9
489 | Muller B, Georgi K, Schnabel A, Schneider B. Does sport have a protective effect against suicide? Epidemiol Psichiatr Soc. 2009 Oct-Dec;18(4):331-5. | 2
490 | Mulye TP, Park M, Nelson CD, Adams SH, Irwin CE, Jr., Brindis CD. Trends in adolescent and young adult health in the United States. Journal of Adolescent Health. 2009 Jul;45(1):8-24. | 4
491 | Mundt JC, Greist JH, Gelenberg AJ, Katzelnick DJ, Jefferson JW, Modell JG. Feasibility and validation of a computer-automated Columbia-Suicide Severity Rating Scale using interactive voice response technology. J Psychiatr Res. 2010 Dec;44(16):1224-8. | 4
492 | Murphy E, Kapur N, Webb R Cooper J. Risk assessment following self-harm: comparison of mental health nurses and psychiatrists. J Adv Nurs. 2011 Jan;67(1): 127-39. | 3
493 | Nademin ME. An investigation of interpersonal-psychological variables in Air force suicides: A controlled-comparison study. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2008;68(9-B):6325. | 3
494 | Naud H, Daigle MS. Predictive validity of the Suicide Probability Scale in a male inmate population. Journal of Psychopathology and Behavioral Assessment. 2010 Sep;32(3):333-42. | 9
495 | Navarro-Mancilla AA, Rueda-Jaimes GE. Internet Addiction: A Critical Review of the Literature. Revista Colombiana de Psiquiatria. 2007 Dec;36(4):691-700. | 1
496 | Nimeus A, Hjalmarsson Stahlfors F, Sunnqvist C, Stanley B, Traskman-Bendz L. Evaluation of a modified interview version and of a self-rating version of the Suicide Assessment Scale. Eur Psychiatry. 2006 Oct;21(7):471-7. | 2
497 | Noble M, Treadwell J, R., Tregear S, J., et al. Long-term opioid management for chronic noncancer pain. Cochrane Database of Systematic Reviews. 2010 (11). | 4
498 | Nock MK, Borges G, Bromet EJ, Cha CB, Kessler RC, Lee S. Suicide and suicidal behavior. Epidemiol Rev. 2008;30:133-54. | 6
499 | Nock MK, Holmberg EB, Photos VI, Michel BD. Self-Injurious Thoughts and Behaviors Interview: Development, reliability, and validity in an adolescent sample. Psychological Assessment. 2007 Sep;19(3):309-17. | 9
500 | Nock MK, Prinstein MJ, Sterba SK. Revealing the form and function of self-injurious thoughts and behaviors: A real-time ecological assessment study among adolescents and young adults. J Abnorm Psychol. 2009 Nov; 118(4):816-27. | 3
501 | Nordentoft M, Branner J. Gender differences in suicidal intent and choice of method among suicide attempters. Crisis. 2008;29(4):209-12. | 2
502 | Norstrom T, Ramstedt M. Mortality and population drinking: a review of the literature. Drug Alcohol Rev. 2005 Nov;24(6):537-47. | 5
503 | Novick DM, Swartz HA, Frank E. Suicide attempts in bipolar I and bipolar II disorder: a review and meta-analysis of the evidence. Bipolar Disord. 2010 Feb; 12(1): 1-9. | 6
504 | O'Connor RC. The relations between perfectionism and suicidality: a systematic review. Suicide Life Threat Behav. 2007 Dec;37(6):698-714. | 6
505 | O'Donovan C, Garnham JS, Hajek T, Alda M. Antidepressant monotherapy in pre-bipolar depression; predictive value and inherent risk. J Affect Disord. 2008 Apr;107(1-3):293-8. | 9
506 | Oldham J. PTSD and suicide. Journal of Psychiatric Practice. 2008 Jul; 14(4): 195. | 5
507 | Oldham J. Visible and invisible wounds. Journal of Psychiatric Practice. 2009 Nov;15(6):429. | 5
508 | Olfson M, Gameroff MJ, Marcus SC, Greenberg T, Shaffer D. Emergency treatment of young people following deliberate self-harm. Arch Gen Psychiatry. 2005 Oct;62(10): 1122-8. | 9
509 | Olmsted CL, Kockler DR. Topiramate for alcohol dependence. Ann Pharmacother. 2008 Oct;42(10): 1475-80. | 6
510 | Olson LM, Wahab S. American Indians and Suicide: A Neglected Area of Research. Trauma, Violence, & Abuse. 2006 Jan;7(1): 19-33. | 5
511 | Omalu B, Hammers JL, Bailes J, et al. Chronic traumatic encephalopathy in an Iraqi war veteran with posttraumatic stress disorder who committed suicide. Neurosurg Focus. 2011 Nov;31(5):E3. | 5
512 | Omar HA. A model program for youth suicide prevention. Int J Adolesc Med Health. 2005 Jul-Sep;17(3):275-8. | 4
513 | Oordt MS, Jobes DA, Rudd M, et al. Development of a Clinical Guide to Enhance Care for Suicidal Patients. Professional Psychology: Research and Practice. 2005 Apr;36(2):208-18. | 5
514 | Opler M, Sodhi D, Zaveri D, Madhusoodanan S. Primary psychiatric prevention in children and adolescents. Annals of Clinical Psychiatry. 2010 Nov;22(4):220-34. | 5
515 | Oquendo M, Currier D, Mann J. Prospective studies of suicidal behavior in major depressive and bipolar disorders: What is the evidence for predictive risk factors? Acta Psychiatrica Scandinavica. 2006 Sep;114(3):151-8. | 6
516 | Oquendo MA, Chaudhury SR Mann J. Pharmacotherapy of Suicidal Behavior in Bipolar Disorder. Archives of Suicide Research. 2005 Sep;9(3):237-50. | 5
517 | Osman A, Barrios FX, Gutierrez PM, Williams JE, Bailey J. Psychometric properties of the Beck Depression Inventory-II in nonclinical adolescent samples. Journal of Clinical Psychology. 2008 Jan;64(1):83-102. | 3
518 | Osman A, Gutierrez PM, Schweers R, Fang Q, Holguin-Mills RL, Cashin M. Psychometric evaluation of the body investment scale for use with adolescents. J Clin Psychol. 2010 Mar;66(3):259-76. | 3
519 | Owens C, Lambert H, Donovan J, Lloyd KR. A qualitative study of help seeking and primary care consultation prior to suicide. Br J Gen Pract. 2005 Jul;55(516):503-9. | 3
520 | Owens C, Owen G, Lambert H, et al. Public involvement in suicide prevention: understanding and strengthening lay responses to distress. BMC Public Health. 2009;9:308. | 3
521 | Owens D, Wood C, Greenwood DC, Hughes T, Dennis M. Mortality and suicide after non-fatal self-poisoning: 16-year outcome study. Br J Psychiatry. 2005 Nov; 187:470-5. | 9
522 | Ozturk S, Bozkurt A, Durmus M, Deveci M, Sengezer M. Psychiatric analysis of suicide attempt subjects due to maxillofacial gunshot. J Craniofac Surg. 2006 Nov;17(6):1072-5. | 2
523 | Pae C-U, Koh JS, Lee S-J, Han C, Patkar AA, Masand PS. Association of sedative-hypnotic medications with suicidality. Expert Review of Neurotherapeutics. 2011 Mar;11(3):345-9. | 5
524 | Page SA, King MC. No-suicide agreements: current practices and opinions in a Canadian urban health region. Can J Psychiatry. 2008 Mar;53(3): 169-76. | 3
525 | Pagura J, Fotti S, Katz LY, Sareen J, Swampy Cree Suicide Prevention T. Help seeking and perceived need for mental health care among individuals in Canada with suicidal behaviors. Psychiatr Serv. 2009 Jul;60(7):943-9. | 9
526 | Palmer BA, Pankratz V, Bostwick JM. The Lifetime Risk of Suicide in Schizophrenia: A Reexamination. Archives of General Psychiatry. 2005 Mar;62(3):247-53. | 6
527 | Palmer S. Suicide statistics for the UK and the National Suicide Prevention Strategy. Palmer, Stephen [Ed]. 2008:27-47. | 5
528 | Panagioti M, Gooding P, Tarrier N. Post-traumatic stress disorder and suicidal behavior: A narrative review. Clinical Psychology Review. 2009 Aug;29(6):471-82. | 6
529 | Parellada M, Saiz P, Moreno D, et al. Is attempted suicide different in adolescent and adults? Psychiatry Res. 2008 Jan 15; 157(1-3): 131-7. | 2
530 | Patorno E, Bohn RL, Wahl PM, et al. Anticonvulsant medications and the risk of suicide, attempted suicide, or violent death. JAMA. 2010 Apr 14;303(14):1401-9. | 9
531 | Pavot W, Diener E. The Satisfaction With Life Scale and the emerging construct of life satisfaction. The Journal of Positive Psychology. 2008 Apr;3(2): 137-52. | 5
532 | Pedersen AG. Citalopram and suicidality in adult major depression and anxiety disorders. Nord J Psychiatry. 2006;60(5):392-9. | 5
533 | Pedersen AG. Escitalopram and suicidality in adult depression and anxiety. Int Clin Psychopharmacol. 2005 May;20(3): 139-43. | 2
534 | Pena JB, Caine ED. Screening as an Approach for Adolescent Suicide Prevention. Suicide and Life Threatening Behavior. 2006 Dec;36(6):614-37. | 6
535 | Peterson J, Skeem J, Manchak S. If you want to know, consider asking: How likely is it that patients will hurt themselves in the future? Psychological Assessment. 2011 Sep;23(3):626-34. | 9
536 | Pettit JW, Garza MJ, Grover KE, et al. Factor structure and psychometric properties of the Modified Scale for Suicidal Ideation among suicidal youth. Depression and Anxiety. 2009 Aug;26(8):769-74. | 3
537 | Phillips KA. Suicidality in body dysmorphic disorder. Primary Psychiatry. 2007 Dec;14(12):58-66. | 5
538 | Pirruccello LM. Preventing adolescent suicide: a community takes action. J Psychosoc Nurs Ment Health Serv. 2010 May;48(5):34-41. | 5
539 | Pisani AR, Cross WF, Gould MS. The Assessment and Management of Suicide Risk: State of Workshop Education. Suicide Life Threat Behav. 2011 Apr 7;41(3):255-76. | 6
540 | Platt B, Hawton K, Simkin S, Mellanby RJ. Suicidal behaviour and psychosocial problems in veterinary surgeons: a systematic review. Soc Psychiatry Psychiatr Epidemiol. 2010 Dec 23. | 3
541 | Ploderl M, Sauer J, Fartacek R. Suicidality and mental health of homosexual and bisexual men and women--a meta analysis of international probability samples. Verhaltenstherapie & Psychosoziale Praxis. 2006 Aug;38(3):537-58. | 1
542 | Pompili M, Di Cosimo D, Innamorati M, Lester D, Tatarelli R, Martelletti P. Psychiatric comorbidity in patients with chronic daily headache and migraine: a selective overview including personality traits and suicide risk. J Headache Pain. 2009 Aug;10(4):283-90. | 5
543 | Pompili M, Girardi P, Ruberto A, Tatarelli R. Suicide in borderline personality disorder: A metaanalysis. Nordic Journal of Psychiatry. 2005 Oct;59(5):319-24. | 5
544 | Pompili M, Girardi P, Ruberto A, Tatarelli R. Suicide in the epilepsies: a meta-analytic investigation of 29 cohorts. Epilepsy Behav. 2005 Sep;7(2):305-10. | 5
545 | Pompili M, Girardi P, Tatarelli G, Ruberto A, Tatarelli R. Suicide and attempted suicide in eating disorders, obesity and weight-image concern. Eating Behaviors. 2006 Oct;7(4):384-94. | 6
546 | Pompili M, Girardi P, Tatarelli R. Death from suicide versus mortality from epilepsy in the epilepsies: a meta-analysis. Epilepsy Behav. 2006 Dec;9(4):641-8. | 5
547 | Pompili M, Innamorati M, Girardi P, Tatarelli R, Lester D. Evidence-based interventions for preventing suicide in youths. In: Pompili M, Tatarelli R eds. Evidence-based practice in suicidology: A source book. Cambridge, MA: Hogrefe Publishing; 2011:171-209. | 6
548 | Pompili M, Innamorati M, Tatarelli R. Suicide and anorexia nervosa. Minerva Psichiatrica. 2007 Dec;48(4):387-96. | 1
549 | Pompili M, Lester D, Innamorati M, et al. Preventing suicide in jails and prisons: Suggestions from experience with psychiatric inpatients. Journal of Forensic Sciences. 2009 Sep;54(5):1155-62. | 3
550 | Pompili M, Mancinelli I, Girardi P, Ruberto A, Tatarelli R. Suicide in Anorexia Nervosa: A Meta-Analysis. International Journal of Eating Disorders. 2004;36(1):99-103. | 5
551 | Pompili M, Mancinelli I, Ruberto A, Kotzalidis GD, Girardi P, Tatarelli R. Where Schizophrenic Patients Commit Suicide: A Review of Suicide among Inpatients and Former Inpatients. International Journal of Psychiatry in Medicine. 2005;35(2): 171-90. | 6
552 | Pompili M, Serafini G, Forte A, Del Casale A, Innamorati M, Tatarelli R. Suicide risk in cancer patients. Medicina Psicosomatica. 2008 Jul-Sep;53(3): 105-16. | 1
553 | Pompili M, Serafini G, Innamorati M, et al. Suicide risk in first episode psychosis: A selective review of the current literature. Schizophr Res. 2011 Jun;129(1):1-11. | 6
554 | Poon LH, Kang GA, Lee AJ. Role of tetrabenazine for Huntington's disease-associated chorea. Ann Pharmacother. 2010 Jun;44(6): 1080-9. | 4
555 | Portzky G, van Heeringen K. Deliberate self-harm in adolescents. Current Opinion in Psychiatry. 2007 Jul;20(4):337-42. | 5
556 | Posey S. Veterans and suicide: A review of potential increased risk. Smith College Studies in Social Work. 2009 Jul;79(3-4):368-74. | 5
557 | Posner K, Melvin GA, Stanley B. Identification and monitoring of suicide risk in primary care settings. Primary Psychiatry. 2007 Dec;14(12):50-5. | 5
558 | Posner K, Oquendo MA, Gould M, Stanley B, Davies M. Columbia Classification Algorithm of Suicide Assessment (C-CASA): classification of suicidal events in the FDA's pediatric suicidal risk analysis of antidepressants. Am J Psychiatry. 2007 Jul;164(7):1035-43. | 5
559 | Posternak MA, Zimmerman M. Therapeutic effect of follow-up assessments on antidepressant and placebo response rates in antidepressant efficacy trials: meta-analysis. British Journal of Psychiatry. 2007;190:287-92. | 6
560 | Preston E, Hansen L. A systematic review of suicide rating scales in schizophrenia. Crisis: The Journal of Crisis Intervention and Suicide Prevention. 2005;26(4): 170-80. | 6
561 | Preti A, Rocchi MB, Sisti D, Camboni MV, Miotto P. A comprehensive meta-analysis of the risk of suicide in eating disorders. Acta Psychiatr Scand. 2011 Jul;124(1):6-17. | 5
562 | Price RK, Chen L-S, Risk NK, et al. Suicide in a natural history study: Lessons and insights learned from a follow-up of Vietnam veterans at risk for suicide. Buchanan, David [Ed]. 2009:109-32. | 3
563 | Probst C, Zelle BA, Sittaro NA, Lohse R Krettek C, Pape HC Late death after multiple severe trauma: when does it occur and what are the causes? J Trauma. 2009 Apr;66(4): 1212-7. | 2
564 | Procter NG. Parasuicide, self-harm and suicide in Aboriginal people in rural Australia: A review of the literature with implications for mental health nursing practice. International Journal of Nursing Practice. 2005 Oct;11(5):237-41. | 5
565 | Purselle DC, Heninger M, Hanzlick R, Garlow SJ. Differential association of socioeconomic status in ethnic and age-defined suicides. Psychiatry Res. 2009 May 30;167(3):258-65. | 9
566 | Quarantini LC, Netto LR Andrade-Nascimento M, et al. Comorbid mood and anxiety disorders in victims of violence with posttraumatic stress disorder. Revista Brasileira de Psiquiatria. 2009 Oct;31(Suppl 2):S66-S76. | 3
567 | Raja M, Azzoni A, Koukopoulos AE. Psychopharmacological treatment before suicide attempt among patients admitted to a psychiatric intensive care unit. J Affect Disord. 2009 Feb; 113(1-2):37-44. | 2
568 | Raja M, Azzoni A. Are antidepressants warranted in the treatment of patients who present suicidal behavior? Hum Psychopharmacol. 2008 Dec;23(8):661-8. | 2
569 | Ramey HL, Busseri MA, Khanna N, Hamilton YN, Ottawa YN, Rose-Krasnor L. Youth engagement and suicide risk: testing a mediated model in a Canadian community sample. J Youth Adolesc. 2010 Mar;39(3):243-58. | 3
570 | Randle AA, Graham CA. A review of the evidence on the effects of intimate partner violence on men. Psychology of Men & Masculinity. 2011 Apr;12(2):97-111. | 5
571 | Reardon CL, Factor RM. Sport psychiatry: a systematic review of diagnosis and medical treatment of mental illness in athletes. Sports Med. 2010 Nov 1;40(11):961-80. | 5
572 | Redden L, Pritchett Y, Robieson W, et al. Suicidality and divalproex sodium: Analysis of controlled studies in multiple indications. Annals of General Psychiatry. 2011 Jan; 10:1. | 7
573 | Reeves RR, Ladner ME. Antidepressant-induced suicidality: An update. CNS Neuroscience & Therapeutics. 2010 Aug;16(4):227-34. | 5
574 | Reeves RR, Ladner ME. Antidepressant-induced suicidality: implications for clinical practice. South Med J. 2009 Jul;102(7):713-8. | 5
575 | Reeves RR, Panguluri RL. Neuropsychiatric complications of traumatic brain injury. J Psychosoc Nurs Ment Health Serv. 2011 Mar;49(3):42-50. | 5
576 | Rehkopf DH, Buka SL. The association between suicide and the socio-economic characteristics of geographical areas: a systematic review. Psychol Med. 2006 Feb;36(2): 145-57. | 6
577 | Reinherz HZ, Tanner JL, Berger SR Beardslee WR, Fitzmaurice GM. Adolescent suicidal ideation as predictive of psychopathology, suicidal behavior, and compromised functioning at age 30. Am J Psychiatry. 2006 Jul; 163(7): 1226-32. | 3
578 | Reutfors J, Bahmanyar S, Jonsson EG, et al. Diagnostic profile and suicide risk in schizophrenia spectrum disorder. Schizophrenia Research. 2010 Nov; 123(2-3):251-6. | 2
579 | Reviere SL, Farber EW, Twomey H, et al. Intimate partner violence and suicidality in low-income African American women: a multimethod assessment of coping factors. Violence Against Women. 2007 Nov;13(11):1113-29. | 9
580 | Reynolds SK, Lindenboim N, Comtois KA, Murray A, Linehan MM. Risky assessments: participant suicidality and distress associated with research assessments in a treatment study of suicidal behavior. Suicide and Life-Threatening Behavior. 2006;36(1): 19-34. | 3
581 | Rhodes AE, Boyle MH, Tonmyr L, et al. Sex differences in childhood sexual abuse and suicide-related behaviors. Suicide Life Threat Behav. 2011 Jun;41(3):235-54. | 6
582 | Ribeiro JD, Pease JL, Gutierrez PM, et al. Sleep problems outperform depression and hopelessness as cross-sectional and longitudinal predictors of suicidal ideation and behavior in young adults in the military. J Affect Disord. 2011 Oct 25. | 8
583 | Richa N, Richa S, Salloum S, Baddoura C, Millet B, Mirabel-Sarron C. Familial risk factors influencing the course and the evolution of bipolar disorder: Literature review. Journal de Therapie Comportementale et Cognitive. 2009 Dec;19(4):141-5. | 1
584 | Richardson T. Correlates of substance use disorder in bipolar disorder: A systematic review and meta-analysis. Mental Health and Substance Use: dual diagnosis. 2011 Aug;4(3):239-55. | 6
585 | Ridenour TA. Inhalants: Not to be taken lightly anymore. Current Opinion in Psychiatry. 2005 May;18(3):243-7. | 5
586 | Rihmer Z, Akiskal H. Do antidepressants t(h)reat(en) depressives? Toward a clinically judicious formulation of the antidepressant-suicidality FDA advisory in light of declining national suicide statistics from many countries. Journal of Affective Disorders. 2006 Aug;94(1-3):3-13. | 5
587 | Rihmer Z, Gonda X. The Effect of Pharmacotherapy on Suicide Rates in Bipolar Patients. CNS Neurosci Ther. 2011 Aug 1. | 5
588 | Rihmer Z. Suicide risk in mood disorders. Current Opinion in Psychiatry. 2007 Jan;20(1): 17-22. | 5
589 | Roaldset JO, Bjorkly S. Patients' own statements of their future risk for violent and self-harm behaviour: A prospective inpatient and post-discharge follow-up study in an acute psychiatric unit. Psychiatry Research. 2010 Jun;178(1):153-9. | 2
590 | Roberts SE, Jaremin B, Chalasani P, Rodgers SE. Suicides among seafarers in UK merchant shipping, 1919-2005. Occupational Medicine. 2010 Jan;60(1):54-61. | 9
591 | Roberts SJ. Health care recommendations for lesbian women. J Obstet Gynecol Neonatal Nurs. 2006 Sep-Oct;35(5):583-91. | 5
592 | Robertson HT, Allison DB. Drugs associated with more suicidal ideations are also associated with more suicide attempts. PLoS One. 2009;4(10):e7312. | 9
593 | Robertson K, Parsons TD, Van Der Horst C, Hall C. Thoughts of death and suicidal ideation in nonpsychiatric human immunodeficiency virus seropositive individuals. Death Studies. 2006 Jun;30(5):455-69. | 9
594 | Robinson J, Harris MG, Harrigan SM, et al. Suicide attempt in first-episode psychosis: a 7.4 year follow-up study. Schizophr Res. 2010 Jan;116(1):1-8. | 9
595 | Robson A, Scrutton F, Wilkinson L, MacLeod F The risk of suicide in cancer patients: a review of the literature. Psychooncology. 2010 Dec;19(12):1250-8. | 6
596 | Rodriguez JR, Quinones-Maldonado R, Alvarado-Pomales A. Military suicide: factors that need to be taken into consideration to understand the phenomena. Bol Asoc Med P R. 2009 Jul-Sep;101(3):33-41. | 5
597 | Rossow I, Romelsjo A. The extent of the ‘prevention paradox’ in alcohol problems as a function of population drinking patterns. Addiction. 2006 Jan;101(1):84-90. | 2
598 | Rowell K, Green B, Guidry J, Eddy J. Factors associated with suicide among African American adult men: A systematic review of the literature. Journal of Men's Health. 2008 Dec;5(4):274-81. | 6
599 | Roy A, Janal MN. Risk factors for suicide attempts among alcohol dependent patients. Arch Suicide Res. 2007;11(2):211-7. | 9
600 | Roy A, Roy M, Janal M. Suicide attempts and ideation in African-American type 1 diabetic patients. Psychiatry Res. 2010 Aug 30;179(1):53-6. | 9
601 | Roy A, Sarchiapone M, Carli V Low resilience in suicide attempters. Arch Suicide Res. 2007;11(3):265-9. | 2
602 | Roy A, Sarchiopone M, Carli V Gene-environment interaction and suicidal behavior. J Psychiatr Pract. 2009 Jul;15(4):282-8. | 5
603 | Roy A. Characteristics of cocaine dependent patients who attempt suicide. Arch Suicide Res. 2009;13(1):46-51. | 9
604 | Roy A. Combination of family history of suicidal behavior and childhood trauma may represent correlate of increased suicide risk. J Affect Disord. 2011 Apr;130(1-2):205-8. | 9
605 | Rubino A, Roskell N, Tennis P, Mines D, Weich S, Andrews E. Risk of suicide during treatment with venlafaxine, citalopram, fluoxetine, and dothiepin: retrospective cohort study. BMJ. 2007 Feb 3;334(7587):242. | 9
606 | Rucci P, Frank E, Scocco P, et al. Treatment-emergent suicidal ideation during 4 months of acute management of unipolar major depression with SSRI pharmacotherapy or interpersonal psychotherapy in a randomized clinical trial. Depress Anxiety. 2011 Apr;28(4):303-9. | 2
607 | Rudd M, Goulding J, Bryan CJ. Student veterans: A national survey exploring psychological symptoms and suicide risk. Professional Psychology: Research and Practice. 2011 Oct;42(5):354-60. | 8
608 | Rutledge CM, Rimer D, Scott M. Vulnerable Goth teens: the role of schools in this psychosocial high-risk culture. J Sch Health. 2008 Sep;78(9):459-64. | 5
609 | Ryan C, Huebner D, Diaz RM, Sanchez J. Family rejection as a predictor of negative health outcomes in white and Latino lesbian, gay, and bisexual young adults. Pediatrics. 2009 Jan;123(1):346-52. | 9
610 | Ryden G, Ryden E, Hetta J. Borderline personality disorder and autism spectrum disorder in females: A cross-sectional study. Clinical Neuropsychiatry: Journal of Treatment Evaluation. 2008 Feb;5(1):22-30. | 2
611 | Sadeghi-Nejad H, Watson R. Premature ejaculation: current medical treatment and new directions (CME). J Sex Med. 2008 May;5(5): 1037-50; quiz 51-2. | 5
612 | Safer DJ, Zito JM. Do antidepressants reduce suicide rates? Public Health. 2007 Apr;121(4):274-7. | 5
613 | Sahin NH, Batigun AD. [Testing the probability of a model to predict suicide risk in high school and university students]. Turk Psikiyatri Derg. 2009 Spring;20(1):28-36. | 1
614 | Sajatovic M, Biswas K, Kilbourne AK, Fenn H, Williford W, Bauer MS. Factors associated with prospective long-term treatment adherence among individuals with bipolar disorder. Psychiatr Serv. 2008 Jul;59(7):753-9. | 8
615 | Sakinofsky I. The current evidence base for the clinical care of suicidal patients: strengths and weaknesses. Can J Psychiatry. 2007 Jun;52(6 Suppl 1):7S-20S. | 6
616 | Sakinofsky I. Treating suicidality in depressive illness. Part 1: current controversies. Can J Psychiatry. 2007 Jun;52(6 Suppl 1):71S-84S. | 6
617 | Sakinofsky I. Treating suicidality in depressive illness. Part 2: does treatment cure or cause suicidality? Can J Psychiatry. 2007 Jun;52(6 Suppl 1):85S-101S. | 6
618 | Santa Mina E, Gallop R, Links P, et al. The Self-Injury Questionnaire: Evaluation of the psychometric properties in a clinical population. Journal of Psychiatric and Mental Health Nursing. 2006 Apr;13(2):221-7. | 9
619 | Sareen J, Afifi TO, McMillan KA, Asmundson GJ. Relationship between household income and mental disorders: Findings from a population-based longitudinal study. Archives of General Psychiatry. 2011 Apr;68(4):419-26. | 9
620 | Sareen J, Cox BJ, Afifi TO, et al. Combat and peacekeeping operations in relation to prevalence of mental disorders and perceived need for mental health care: findings from a large representative sample of military personnel. Arch Gen Psychiatry. 2007 Jul;64(7):843-52. | 3
621 | Sareen J, Cox BJ, Stein MB, Afifi TO, Fleet C, Asmundson GJ. Physical and mental comorbidity, disability, and suicidal behavior associated with posttraumatic stress disorder in a large community sample. Psychosom Med. 2007 Apr;69(3):242-8. | 9
622 | Sareen J, Stein MB, Thoresen S, Belik SL, Zamorski M, Asmundson GJ. Is peacekeeping peaceful? A systematic review. Can J Psychiatry. 2010 Jul;55(7):464-72. | 6
623 | Sarkar NN. Childhood sexual abuse and its impact on woman's health. International Medical Journal. 2010 Jun;17(2):107-12. | 5
624 | Saunders KE, Hawton K. Suicidal behaviour and the menstrual cycle. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2006 Jul;36(7):901-12. | 6
625 | Schafer DW. Causes and rates of death among help-seeking male Vietnam veterans treated for PTSD: A follow-up study. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2008;69(5-B):3277. | 3
626 | Schneeweiss S, Patrick AR, Solomon DH, et al. Comparative safety of antidepressant agents for children and adolescents regarding suicidal acts. Pediatrics. 2010 May;125(5):876-88. | 9
627 | Schneeweiss S, Patrick AR, Solomon DH, et al. Variation in the risk of suicide attempts and completed suicides by antidepressant agent in adults: a propensity score-adjusted analysis of 9 years' data. Arch Gen Psychiatry. 2010 May;67(5):497-506. | 9
628 | Schneider B, Bartusch B, Schnabel A, Fritze J. [Age and gender: confounders for axis I disorders as risk factors for suicide]. Psychiatr Prax. 2005 May;32(4): 185-94. | 1
629 | Schneider B, Georgi K, Weber B, Schnabel A, Ackermann H, Wetterling T. [Risk factors for suicide in substance-related disorders]. Psychiatr Prax. 2006 Mar;33(2):81-7. | 1
630 | Schneider R, Burnette ML, Ilgen MA, Timko C. Prevalence and correlates of intimate partner violence victimization among men and women entering substance use disorder treatment. Violence Vict. 2009;24(6):744-56. | 9
631 | Scholz BA, Hammonds CL, Boomershine CS. Duloxetine for the management of fibromyalgia syndrome. J Pain Res. 2009;2:99-108. | 5
632 | Schulte PF. Risk of clozapine-associated agranulocytosis and mandatory white blood cell monitoring. Ann Pharmacother. 2006 Apr;40(4):683-8. | 3
633 | Schumock GT, Lee TA, Joo MJ, Valuck RJ, Stayner LT, Gibbons RD. Association between Leukotriene-Modifying Agents and Suicide: What is the Evidence? Drug Saf. 2011 Jul 1;34(7):533-44. | 6
634 | Scoville SL, Gubata ME, Potter RN, White MJ, Pearse LA. Deaths attributed to suicide among enlisted U.S. armed forces recruits, 1980-2004. Military Medicine. 2007 Oct;172(10): 1024-31. | 8
635 | Seemuller F, Lewitzka U, Muller HJ. In people taking antidepressants, suicidal behaviour is less common when they are taking them than in unexposed periods. Evid Based Ment Health. 2011 Nov;14(4):98. | 5
636 | Semiz UB, Basoglu C, Oner O, et al. Effects of diagnostic comorbidity and dimensional symptoms of attention-deficit-hyperactivity disorder in men with antisocial personality disorder. Aust N Z J Psychiatry. 2008 May;42(5):405-13. | 2
637 | Shah A. Psychiatry of old age and ethnic minority older people in the United Kingdom. Reviews in Clinical Gerontology. 2009 May;19(2):119-34. | 5
638 | Shahid M, Hyder AA. Deliberate self-harm and suicide: a review from Pakistan. Int J Inj Contr Saf Promot. 2008 Dec;15(4):233-41. | 2
639 | Sharma S, Sharma M. Stress-induced psychological vital signs in military domain: Assessment and intervention issues. Psychological Studies. 2008 Jan;53(1):7-19. | 5
640 | Sher L. Alcoholism and suicidal behavior: A clinical overview. Acta Psychiatrica Scandinavica. 2006 Jan;113(1):13-22. | 5
641 | Sher L. Brain-derived neurotrophic factor and suicidal behavior. QJM. 2011 May;104(5):455-8. | 5
642 | Shields LB, Hunsaker DM, Hunsaker JC, III. Schizophrenia and suicide: A 10-year review of Kentucky Medical Examiner cases. Journal of Forensic Sciences. 2007 Jul;52(4):930-7. | 4
643 | Shreeram SS, Malik A. Suicidality in the juvenile justice environment. International Journal of Child Health and Human Development. 2008;1(3,Spec Iss):245-60. | 6
644 | Simon GE, Savarino J, Operskalski B, Wang PS. Suicide risk during antidepressant treatment. Am J Psychiatry. 2006 Jan;163(1):41-7. | 9
645 | Simon NM, Pollack MH, Fischmann D, et al. Complicated grief and its correlates in patients with bipolar disorder. J Clin Psychiatry. 2005 Sep;66(9):1105-10. | 9
646 | Simpson G, Franke B, Gillett L. Suicide prevention training outside the mental health service system: evaluation of a state-wide program in Australia for rehabilitation and disability staff in the field of traumatic brain injury. Crisis. 2007;28(1):35-43. | 3
647 | Simpson G, Tate R. Suicidality in people surviving a traumatic brain injury: prevalence, risk factors and implications for clinical management. Brain Inj. 2007 Dec;21(13-14): 1335-51. | 6
648 | Sinclair JM, Gray A, Hawton K. Systematic review of resource utilization in the hospital management of deliberate self-harm. Psychol Med. 2006 Dec;36(12):1681-93. | 3
649 | Singh T, Williams K. Atypical depression. Psychiatry. 2006 Apr;3(4):33-9. | 3
650 | Skegg K, Firth H, Gray A, Cox B. Suicide by occupation: does access to means increase the risk? Aust N Z J Psychiatry. 2010 May;44(5):429-34. | 9
651 | Skopp NA, Luxton DD, Bush N, Sirotin A. Childhood adversity and suicidal ideation in a clinical military sample: Military unit cohesion and intimate relationships as protective factors. Journal of Social and Clinical Psychology. 2011 Apr;30(4):361-77. | 8
652 | Skruibis P, Gailiene D, Kazlauskas E. Level of hopelessness, attitudes towards suicide and suicide risk. Psichologija. 2008;37:44-56. | 1
653 | Slee N, Garnefski N, van der Leeden R, Arensman E, Spinhoven P. Cognitive-behavioural intervention for self-harm: Randomised controlled trial. British Journal of Psychiatry. 2008 Mar;192(3):202-11. | 2
654 | Smith EG, Craig TJ, Ganoczy D, Walters HM, Valenstein M. Treatment of Veterans with depression who died by suicide: timing and quality of care at last Veterans Health Administration visit. J Clin Psychiatry. 2011 Sep 7;72(5):622-9. | 4
655 | Smith EG. Association between antidepressant half-life and the risk of suicidal ideation or behavior among children and adolescents: confirmatory analysis and research implications. J Affect Disord. 2009 Apr;114(1-3):143-8. | 6
656 | Smyth CL, MacLachlan M. Confirmatory Factor Analysis of the Trinity Inventory of Precursors to Suicide (TIPS) and its Relationship to Hopelessness and Depression. Death Studies. 2005 May;29(4):333-50. | 3
657 | Snarr JD, Heyman RE, Slep AM. Recent suicidal ideation and suicide attempts in a large-scale survey of the U.S. Air Force: prevalences and demographic risk factors. Suicide Life Threat Behav. 2010 Dec;40(6):544-52. | 8
658 | Soyka M, Schmidt P. Outpatient alcoholism treatment--24-month outcome and predictors of outcome. Subst Abuse Treat Prev Policy. 2009;4:15. | 9
659 | Speckens AE, Hawton K. Social problem solving in adolescents with suicidal behavior: a systematic review. Suicide Life Threat Behav. 2005 Aug;35(4):365-87. | 6
660 | Spiegel B, Schoenfeld P, Naliboff B. Systematic review: the prevalence of suicidal behaviour in patients with chronic abdominal pain and irritable bowel syndrome. Aliment Pharmacol Ther. 2007 Jul 15;26(2):183-93. | 6
661 | Stanley N, Mallon S, Bell J, Manthorpe J. Suicidal students' use of and attitudes to primary care support services. Primary Health Care Research and Development. 2010 Oct;11(4):315-25. | 3
662 | Stapleton J. Do the 10 UK suicides among those taking the smoking cessation drug varenicline suggest a causal link? Addiction. 2009 May;104(5):864-5. | 5
663 | Steele MM, Doey T. Suicidal behaviour in children and adolescents. part 1: etiology and risk factors. Can J Psychiatry. 2007 Jun;52(6 Suppl 1):21S-33S. | 6
664 | Stefansson J, Nordstrom P, Jokinen J. Suicide Intent Scale in the prediction of suicide. J Affect Disord. 2010 Dec 8. | 2
665 | Stone M, Laughren T, Jones ML, et al. Risk of suicidality in clinical trials of antidepressants in adults: analysis of proprietary data submitted to US Food and Drug Administration. BMJ. 2009;339:b2880. | 7
666 | Strauss JL, Calhoun PS, Marx CE, et al. Comorbid posttraumatic stress disorder is associated with suicidality in male veterans with schizophrenia or schizoaffective disorder. Schizophr Res. 2006 May;84(1): 165-9. | 8
667 | Strutt AM, Simpson R Jankovic J, York MK. Changes in cognitive-emotional and physiological symptoms of depression following STN-DBS for the treatment of Parkinson's disease. Eur J Neurol. 2011 Jun 11. | 9
668 | Studdert DM, Gurrin LC, Jatkar U, Pirkis J. Relationship between vehicle emissions laws and incidence of suicide by motor vehicle exhaust gas in Australia, 2001-06: an ecological analysis. PLoS Med. 2010 Jan;7(1):e1000210. | 3
669 | Sumner SA, Layde PM, Guse CE. Firearm death rates and association with level of firearm purchase background check. Am J Prev Med. 2008 Jul;35(1):1-6. | 3
670 | Szumilas M, Kutcher S. Teen suicide information on the internet: a systematic analysis of quality. Can J Psychiatry. 2009 Sep;54(9):596-604. | 5
671 | Tang NK, Crane C. Suicidality in chronic pain: a review of the prevalence, risk factors and psychological links. Psychol Med. 2006 May;36(5):575-86. | 6
672 | Taur FM, Chai S, Chen MB, Hou JL, Lin S, Tsai SL. Evaluating the suicide risk-screening scale used by general nurses on patients with chronic obstructive pulmonary disease and lung cancer: a questionnaire survey. J Clin Nurs. 2011 Aug 1. | 2
673 | Taylor J, Kemper TS, Loney BR, Kistner JA. Classification of severe male juvenile offenders using the MACI clinical and personality scales. J Clin Child Adolesc Psychol. 2006 Feb;35(1):90-102. | 9
674 | Taylor PJ, Gooding P, Wood AM, Tarrier N. The role of defeat and entrapment in depression, anxiety, and suicide. Psychol Bull. 2011 May;137(3):391-420. | 3
675 | Teasdale T, Engberg A. Suicide after traumatic brain injury: a population study. Journal of Neurology, Neurosurgery & Psychiatry. 2001;71(4):436-40. | 2
676 | Thomas SH, Drici MD, Hall GC, et al. Safety of sertindole versus risperidone in schizophrenia: principal results of the sertindole cohort prospective study (SCoP). Acta Psychiatrica Scandinavica. 2010 Nov;122(5):345-55. | 2
677 | Thompson R, Kane V, Cook JM, Greenstein R Walker P, Woody G Suicidal ideation in veterans receiving treatment for opiate dependence. J Psychoactive Drugs. 2006 Jun;38(2): 149-56. | 3
678 | Thorell L. Valid electrodermal hyporeactivity for depressive suicidal propensity offers links to cognitive theory. Acta Psychiatrica Scandinavica. 2009 May;119(5):338-49. | 5
679 | Thoresen S, Mehlum L, Roysamb E, Tonnessen A. Risk factors for completed suicide in veterans of peacekeeping: repatriation, negative life events, and marital status. Arch Suicide Res. 2006;10(4):353-63. | 2
680 | Thoresen S, Mehlum L. Suicide in peacekeepers: risk factors for suicide versus accidental death. Suicide Life Threat Behav. 2006 Aug;36(4):432-42. | 2
681 | Thoresen S, Mehlum L. Traumatic stress and suicidal ideation in Norwegian male peacekeepers. J Nerv Ment Dis. 2008 Nov;196(11):814-21. | 2
682 | Tondo L, Baldessarini RJ. Long-term lithium treatment in the prevention of suicidal behavior in bipolar disorder patients. Epidemiol Psichiatr Soc. 2009 Jul-Sep;18(3): 179-83. | 5
683 | Troister T, Links PS, Cutcliffe J. Review of predictors of suicide within 1 year of discharge from a psychiatric hospital. Curr Psychiatry Rep. 2008 Feb;10(1):60-5. | 6
684 | Tsai SJ, Hong CJ, Liou YJ. Recent molecular genetic studies and methodological issues in suicide research. Prog Neuropsychopharmacol Biol Psychiatry. 2010 Oct 23. | 6
685 | Turner O, Windfuhr K, Kapur N. Suicide in deaf populations: a literature review. Ann Gen Psychiatry. 2007;6:26. | 6
686 | Uebelacker LA, German NM, Gaudiano BA, Miller IW Patient health questionnaire depression scale as a suicide screening instrument in depressed primary care patients: A cross-sectional study [NCT00541957]. Primary Care Companion to the Journal of Clinical Psychiatry. 2011;13(1):e1-e6. | 3
687 | Utsey SO, Hook JN, Stanard P. A re-examination of cultural factors that mitigate risk and promote resilience in relation to African American suicide: A review of the literature and recommendations for future research. Death Studies. 2007;31(5):399-416. | 5
688 | Valente SM, Saunders J. Screening for depression and suicide: self-report instruments that work. J Psychosoc Nurs Ment Health Serv. 2005 Nov;43(11):22-31. | 5
689 | van den Bosch LM, Verheul R. Patients with addiction and personality disorder: Treatment outcomes and clinical implications. Current Opinion in Psychiatry. 2007 Jan;20(1):67-71. | 5
690 | Van Orden KA, Witte TK, Holm-Denoma J, Gordon KH, Joiner TE, Jr. Suicidal behavior on Axis VI: Clinical data supporting a sixth axis for DSM-V Crisis: The Journal of Crisis Intervention and Suicide Prevention. 2011;32(2): 110-3. | 3
691 | VanCott AC, Cramer JA, Copeland LA, et al. Suicide-related behaviors in older patients with new anti-epileptic drug use: data from the VA hospital system. BMC Med. 2010;8:4. | 3
692 | Vitiello B, Silva SG, Rohde P, et al. Suicidal events in the Treatment for Adolescents With Depression Study (TADS). J Clin Psychiatry. 2009 May;70(5):741-7. | 4
693 | Voracek M, Loibl LM. Consistency of immigrant and country-of-birth suicide rates: a metaanalysis. Acta Psychiatr Scand 2008 Oct;118(4):259-71. | 6
694 | Voracek M, Loibl LM. Genetics of suicide: a systematic review of twin studies. Wien Klin Wochenschr. 2007;119(15-16):463-75. | 6
695 | Wagenaar AC, Toomey TL. Effects of minimum drinking age laws: a review and analyses of the literature from 1960 to 2000. Journal of Studies on Alcohol. 2002 (Supplement 14):206-25. | 3
696 | Wagner KD, Jonas J, Findling RL, Ventura D, Saikali K. A double-blind, randomized, placebo-controlled trial of escitalopram in the treatment of pediatric depression. J Am Acad Child Adolesc Psychiatry. 2006 Mar;45(3):280-8. | 9
697 | Walker J, Hansen CH, Hodges L, et al. Screening for suicidality in cancer patients using Item 9 of the nine-item patient health questionnaire; does the item score predict who requires further assessment? Gen Hosp Psychiatry. 2010 Mar-Apr;32(2):218-20. | 3
698 | Walker R, Cole JE, Logan T, Corrigan JD. Screening substance abuse treatment clients for traumatic brain injury: Prevalence and characteristics. The Journal of Head Trauma Rehabilitation. 2007 Nov-Dec;22(6):360-7. | 9
699 | Wallin MT, Wilken JA, Turner AP, Williams RM, Kane R. Depression and multiple sclerosis: Review of a lethal combination. J Rehabil Res Dev. 2006 Jan-Feb;43(1):45-62. | 5
700 | Walsh S, Clayton R, Liu L, Hodges S. Divergence in contributing factors for suicide among men and women in Kentucky: recommendations to raise public awareness. Public Health Rep. 2009 Nov-Dec;124(6):861-7. | 9
701 | Warner CH, Appenzeller GN, Parker JR, Warner C, Diebold CJ, Grieger T. Suicide prevention in a deployed military unit. Psychiatry. 2011 Summer;74(2):127-41. | 4
702 | Warner CH, Breitbach JE, Appenzeller GN, Yates V, Grieger T, Webster WG Division mental health in the new brigade combat team structure: part II. Redeployment and postdeployment. Mil Med. 2007 Sep;172(9):912-7. | 4
703 | Webb L. Counting girls out: A review of suicide among young substance misusers and gender difference implications in the evaluation of risk. Drugs: Education, Prevention & Policy. 2009 Apr;16(2): 103-26. | 5
704 | Webb RT, Marshall CE, Abel KM. Teenage motherhood and risk of premature death: long-term follow-up in the ONS Longitudinal Study. Psychol Med. 2011 Jan 28:1-11. | 9
705 | Weich S, Patterson J, Shaw R Stewart-Brown S. Family relationships in childhood and common psychiatric disorders in later life: systematic review of prospective studies. Br J Psychiatry. 2009 May;194(5):392-8. | 6
706 | Weiner J, Richmond TS, Conigliaro J, Wiebe DJ. Military veteran mortality following a survived suicide attempt. BMC Public Health. 2011 May 23;11(1):374. | 4
707 | Welton R. The management of suicidality: Assessment and intervention. Psychiatry. 2007 May;4(5):24-32. | 5
708 | Werry JS. Predicting completed suicide. Journal of the American Academy of Child & Adolescent Psychiatry. 2007 Sep;46(9):1097. | 5
709 | White N, Litovitz T, Clancy C. Suicidal antidepressant overdoses: a comparative analysis by antidepressant type. J Med Toxicol. 2008 Dec;4(4):238-50. | 9
710 | Whitlock J, Eckenrode J, Silverman D. Self-injurious behaviors in a college population. Pediatrics. 2006 Jun;117(6):1939-48. | 3
711 | Wilcox HC, Storr CL, Breslau N. Posttraumatic stress disorder and suicide attempts in a community sample of urban American young adults. Arch Gen Psychiatry. 2009 Mar;66(3):305-11. | 9
712 | Williams JW, Jr., Slubicki MN, Tweedy DS, Bradford DW, Trivedi RB, Baker D. Determining the Responsiveness of Depression Questionnaires and Optimal Treatment Duration for Antidepressant Medications. 2009 Oct Questionnaires and Optimal Treatment Duration for Antidepressant Medications. | 3
713 | Witte TK, Joiner TE, Jr., Brown GK, et al. Factors of suicide ideation and their relation to clinical and other indicators in older adults. Journal of Affective Disorders. 2006 Aug;94(1-3): 165-72. | 3
714 | Wockel L, Goth K, Matic N, Zepf FD, Holtmann M, Poustka F. Psychopharmacotherapy in adolescents with borderline personality disorder in inpatient and outpatient psychiatric treatment. Zeitschrift fur Kinder- und Jugendpsychiatrie und Psychotherapie. 2010 Jan;38(1):37-49. | 1
715 | Wohlfarth TD, van Zwieten BJ, Lekkerkerker FJ, et al. Antidepressants use in children and adolescents and the risk of suicide. Eur Neuropsychopharmacol. 2006 Feb;16(2):79-83. | 7
716 | Wojcik BE, Akhtar FZ, Hassell LH. Hospital admissions related to mental disorders in U.S. Army soldiers in Iraq and Afghanistan. Mil Med. 2009 Oct;174(10): 1010-8. | 8
717 | Woo J-M, Postolache TT. The impact of work environment on mood disorders and suicide: Evidence and implications. International Journal on Disability and Human Development. 2008 Apr-Jun;7(2): 185-200. | 6
718 | Woodhead C, Rona RJ, Iversen A, et al. Mental health and health service use among post-national service veterans: results from the 2007 Adult Psychiatric Morbidity Survey of England. Psychol Med. 2011 Feb;41(2):363-72. | 9
719 | Wortzel HS, Binswanger IA, Anderson CA, Adler LE. Suicide among incarcerated veterans. J Am Acad Psychiatry Law. 2009;37(1):82-91. | 6
720 | Yackel EE, McKennan MS, Fox-Deise A. A nurse-facilitated depression screening program in an Army primary care clinic: an evidence-based project. Nurs Res. 2010 Jan-Feb;59(1 Suppl):S58-65. | 3
721 | Yamane GK, Butler JL. Suicide burden in the U.S. Air Force: 1990-2004. Mil Med. 2009 Oct;174(10):1019-23. | 8
722 | Yang AC, Tsai SJ, Huang NE. Decomposing the association of completed suicide with air pollution, weather, and unemployment data at different time scales. J Affect Disord. 2011 Mar;129(1-3):275-81. | 2
723 | Yoon YH, Chen CM, Yi HY, Moss HB. Effect of comorbid alcohol and drug use disorders on premature death among unipolar and bipolar disorder decedents in the United States, 1999 to 2006. Compr Psychiatry. 2010 Dec 10. | 9
724 | Young KA, Bonkale WL, Holcomb LA, Hicks PB, German DC. Major depression, 5HTTLPR genotype, suicide and antidepressant influences on thalamic volume. Br J Psychiatry. 2008 Apr; 192(4):285-9. | 3
725 | Youssef NA, Rich CL. Does acute treatment with sedatives/hypnotics for anxiety in depressed patients affect suicide risk? A literature review. Annals of Clinical Psychiatry. 2008;20(3): 157-69. | 6
726 | Yurgelun-Todd DA, Bueler CE, McGlade EC, Churchwell JC, Brenner LA, Lopez-Larson MP. Neuroimaging correlates of traumatic brain injury and suicidal behavior. J Head Trauma Rehabil. 2011 Jul-Aug;26(4):276-89. | 3
727 | Zamorski MA. Suicide prevention in military organizations. Int Rev Psychiatry. 2011 Apr;23(2): 173-80. | 6
728 | Zhang J, McKeown RE, Hussey JR, Thompson SJ, Woods JR. Gender differences in risk factors for attempted suicide among young adults: Findings from the Third National Health and Nutrition Examination Survey. Annals of Epidemiology. 2005;15(2):167-74. | 9
729 | Zisook S, Rush AJ, Lesser I, et al. Preadult onset vs. adult onset of major depressive disorder: a replication study. Acta Psychiatr Scand. 2007 Mar; 115(3): 196-205. | 9
730 | Zisook S, Trivedi MH, Warden D, et al. Clinical correlates of the worsening or emergence of suicidal ideation during SSRI treatment of depression: an examination of citalopram in the STAR*D study. J Affect Disord. 2009 Sep;117(1-2):63-73. | 9
731 | Zivin K, Eisenberg D, Gollust SE, Golberstein E. Persistence of mental health problems and needs in a college student population. J Affect Disord. 2009 Oct; 117(3): 180-5. | 3
732 | Zivin K, Pfeiffer PN, McCammon RJ, et al. “No-shows”: who fails to follow up with initial behavioral health treatment? Am J Manag Care. 2009 Feb;15(2): 105-12. | 3