# ABBREVIATIONS

Abbreviation: Term
ASI: Addiction Severity Index
ASQ: Affective States Questionnaire
BDI: Beck Depression Inventory
CCHS-CFS: Canadian Community Health Survey Cycle 1.2 - Canadian Forces Supplement
CI: Confidence interval
CIDI: Composite International Diagnostic Interview
DoD: Department of Defense
DSM: Diagnostic and Statistical Manual of Mental Disorders
EBPWG: Evidence Based Practice Working Group
EMR: Electronic medical record
FY: Fiscal year
HR: Hazard ratio
ICD: International Classification of Diseases
IPS: Interpersonal Psychological Survey
LHSV: Large Health Survey of Veterans
MCS: Mental Component Summary
MDD: Major Depressive Disorder
N/A: Not applicable
NARDEP: National Registry for Depression
NDI: National Death Index
NICE: National Institute for Health and Clinical Excellence
NS: Not significant
OCD: Obsessive-compulsive disorder
OEF: Operation Enduring Freedom
OIF: Operation Iraqi Freedom
OR: Odds ratio
PAI: Personality Assessment Inventory
PHQ: Patient Health Questionnaire
PTSD: Post-traumatic stress disorder
PY: Person-year
RR: Relative risk
SD: Standard deviation
SPI: Suicide Potential Index
TBI: Traumatic brain injury
UK: United Kingdom
US: United States
VA: Veterans Affairs
VAMC: Veterans Affairs Medical Center
VHA: Veterans Health Administration
vs: Versus