# PEER REVIEW COMMENTS AND AUTHOR RESPONSES

Reviewer | Comment | Response
Question 1. Are the objectives, scope, and methods for this review clearly described?
2 | The concerns addressed in answers 2 and 3 could, perhaps, have been addressed with a more complete discussion of objectives, scope, and methods. | We have revised and expanded the description of scope and methods section to provide a more detailed explanation of the EBPWG requests.
2 | Moreover, the text does not describe how issues of statistical power of the studies reported was addressed. | Statistical power for studies of predictive tools and variables is included in the quality (risk of bias) assessment. In this report, we use the following question in our quality (risk of bias) assessment for each study: “Was the sample size adequate (including adequate number of outcome events)?” was part of our quality (risk of bias) assessment for each study – see Appendix K. We have also added additional detail in the Methods section to make this clearer.
2 | Nor does it address the potential problems and pitfalls in the identification of suicide attempts as outcomes. | We briefly addressed the limitations of suicide attempts as outcomes in that section of results, but have added identification of suicide attempts to the Limitations section of the report as well, to further emphasize that issue.
3 | Within the review it is stated that key questions 3 and 4 were considered but not addressed because of the adequate volume of evidence identified for the first two questions; however, based on the outcomes (limited recommendations) I am not sure I concur. | We established the scope of this report with the EBPWG. Because non-VA literature is less directly applicable to the VA and DOD populations than literature that reports on data from Veteran and military populations, those studies constitute a weaker body of evidence, given the focus of this review. Along with the EBPWG, we agreed that a detailed look at the strongest body of evidence would be most helpful and that a summary of prior systematic reviews for non-VA populations would suffice. Therefore, we have removed reference to questions 3 and 4 (non-Veteran and non-military populations) from the report since it was confusing to readers.
6 | For the most part, these are described well. I was confused by the Table of contents listing 4 key questions, but only 2 of them appearing in the Executive Summary. I think you need to explain in the Executive Summary why you did not address KQs 3 and 4. You may want to explicate further what you mean by finding a sufficient volume of evidence to not do KQ 3 and 4 | See above.
Question 2. Is there any indication of bias in our synthesis of the evidence?
2 | The reasons provided in the draft document for not addressing questions 3 and 4 do not make sense. Ignoring these questions appears to reflect some unspecified goals. | See above.
7 | Unsure about why some questions were not addressed | See above.
Question 3. Are there any published or unpublished studies that we may have overlooked?
1 | The AJPH March 2012 issue on suicide- a study by Bossarte on attempters might be useful. | We agree that this issue provides potentially valuable information on suicide among Veteran and military populations; however the publication date puts it out of the scope of this systematic review. While not identified systematically nor quality rated, it cannot be included in this report. However, we reviewed the Bossarte et al. study informally: They assessed age, gender, race, mental health status and social/emotional support as risk factors for self-reported suicide attempts on the BFSS. A report of depression, anxiety or PTSD carried an adjusted OR of 21.7 (CI 5.6-84.3); no other factors were significant. Even if included, this study would not add significantly to or change the conclusions of our current report.
2 | The rationale for starting the literature review in 2005 is not clearly defined. Basing it on the Mann review does not make sense because that review does not address assessment instruments or risk factors. Basing it on the Gaynes review does not make sense because that publication reviewed relevant literature only until 2002. | The Mann review does review assessment tools. We have clarified the scope and this decision as being based on EBPWG request for the strongest and most directly applicable recent literature on Veterans and members of the military (given the existing literature on civilian populations through such reports as Mann, Gaynes, NICE 2011, Brown, and Goldston). Additionally, we have further summarized the information obtained from other, similar systematic reviews throughout the report to present a more comprehensive review of the literature.
2 | It may be useful to include information from merged data on Veterans utilizing VHA services and the NDA, or from VA records on suicide attempts. | Per follow-up discussions with our stakeholder group, we will not include these unpublished data in this report, but the CPG may choose to make use of such raw data as appropriate.
3 | Would highly consider adding: information and discussion regarding warning signs (Risk factors are very helpful in terms of understanding behaviors at a population-based level. The field is moving towards warning signs [individualized thoughts/behaviors] that precipitate SDV | We have added a discussion of warning signs in the Future Directions section.
3 | Would consider adding non-Veteran/military data. | We have clarified the scope and this decision was based on EBPWG request for recent literature on Veterans and members of the military (given the existing literature on civilian populations through such reports as Mann, Gaynes, NICE 2011, Brown, and Goldston). Additionally, we have further summarized the information obtained from other, similar systematic reviews throughout the report to present a more comprehensive review of the literature.
4 | Helpful information might exist in the work of the VA National Center for Patient Safety, which is not included in this report (for obvious reasons). It might be useful to point this out and refer readers to NCPS | Per follow-up discussions with our stakeholder group, we will not include such data in this report, but the CPG may choose to make use of such raw data as appropriate.
6 | I was slightly surprised that you did not find manuscripts linking Patient Health Questionnaire (PHQ) item scores and suicide behavior or ideation. The PHQ-9^th^ item specifically asks about suicidal ideation. A lot of studies have been done using the PHQ in recently years--you may want to consider do some additional very focused search for manuscripts written about the PHQ and possible suicide-related outcomes. | We did not find any articles evaluating the PHQ-9 that met our inclusion criteria. We have added a discussion of the PHQ-9 and recent literature on the PHQ-9 with regard to suicidality to the Recommendations for Future Research section of this report.
7 | The rationale for starting the literature review in 2005 does not make sense. | We have clarified the scope and this decision was based on EBPWG request for recent literature on Veterans and members of the military (given the existing literature on civilian populations through such reports as Mann, Gaynes, NICE 2011, Brown, and Goldston). Additionally, we have further summarized the information obtained from other, similar systematic reviews throughout the report to present a more comprehensive review of the literature.
7 | I think there are unpublished VA reports that could have been solicited. | Per follow-up discussions with our stakeholder group, we will not include these unpublished data in this report, and the CPG may choose to make use of such raw data as appropriate.
Question 4. Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | In discussing mental health diagnosis as a potential risk factor, it might be helpful to differentiate clinician-generated MH diagnosis versus those from administrative or existing data- as getting a diagnosis in the chart might indicate treatment engagement | We have added this point to the limitations section.
1 | Some of the NDI studies involving national VA databases included VA users, who may not all be Veterans (i.e. some non-Veterans received care at VA facilities). It would be important to note this distinction. | While this may be true in some studies, we anticipate that there are low numbers of non-Veterans included in the VA databases and it may not be possible to identify them individually. Additionally, these people are still members of the Veteran community, which is a population of interest in these studies.
3 | Previous section and include citations: Throughout document would change “Completed Suicide” which sounds like a positive event to “Death by Suicide” | We have now cited both Crosby and Brenner articles on the topic, and clarified terminology throughout, including removal of the term “completed” throughout the entire report. However, we use terms (e.g., suicide attempt) as they were reported in the primary studies in order to provide accurate information from these studies.
3 | Evidence Report – Page 1, some of citations at bottom of page (e.g., are non military/VA sources) this is not clear from reading the text. | We acknowledge that the introduction to this report cites some studies that are not from military or Veteran populations. This section is meant to explain that there are factors derived from military experience that have reasonable likelihood of contributing to increased suicide risk. We have added a citation for TBI that includes Veteran population (Brenner, 2011).
3 | Figure 1 and 2 – Known risk factors don't always lead to distal health outcomes (at least directly) – this is where adding warning signs may be helpful | We have added wording to the Future Research section to acknowledge that warning signs may signify a more immediate state of risk than traditional risk factors which reflect a state of overall heightened risk.
3 | Systematic Reviews – page 12 – it may be helpful to explain how or why using chart data (PAI scores) that were entered by the patient before the attempt would be biased? | In this section, we specifically describe the risk of bias due to lack of assessor blinding as related to chart review methods for assessment of suicide attempts. This outcome is potentially influenced by lack of assessor blinding because of it is not as objective or clearly defined as a test score that is included in a patient's chart. We agree that chart review along for determination of a previously collected assessment tool score would carry a low risk of bias for that outcome.
3 | Summary and Discussion – Page 24 – it is not clear that the limitations of the Hendin study are sufficiently highlighted (Citation 10) | We have added a statement describing the risk of bias for this study.
3 | Summary and Discussion – Page 24 – is the ASI still nationally implemented? – it was my understanding that it was replaced | We have corrected this information throughout the report.
3 | Summary and Discussion – Page 24 – would be important to clarify that the PAI study was only with veterans who had TBIs. | We have added this information.
3 | Summary and Discussion – Page 25 – would be helpful to have citations in attempt and suicide paragraphs. | We have added citations to the Summary and Discussion section.
4 | I don't have much to add. I think the synthesis is very timely since many clinicians and administrators continue to search for an instrument or set of variables to predict suicide in an individual patient. We know (or think we know) that some interventions are useful for the entire population but still struggle with prediction in individual cases. | Noted.
5 | The executive summary has a few typos: p3, line 28 information about specificity is missing; p4. line 9 the name of the instrument being discussed is missing; | We have made these corrections.
5 | p5. line 21 (and elsewhere in the article) the term “Religious Terror” is very confusing – what does it mean? | The term “religious terror” comes directly from the article that assessed this risk factor (Belik 2009). It is the variable name associated with the question: “Have you ever lived as a civilian in a place where there was ongoing terror of civilians for political, ethnic, religious, or other reasons?” We have clarified this in the text and table.
6 | I think you need to confirm your nomenclature matches new national VA standards on nomenclature related to suicide behaviors. This nomenclature should be acknowledged early and clearly—a table may help. The document currently does not use the nomenclature consistently. | We have now cited both Crosby and Brenner articles on the topic, and clarified terminology throughout, including removal of the term “completed” throughout the entire report. However, we use terms (e.g., suicide attempt) as they were reported in the primary studies in order to provide accurate information from these studies.
6 | Related to above, it is unclear to me if suicidal ideation is considered an outcome you looked at—what behaviors were and weren't included? | See above; we have clarified terminology related to outcomes and state that suicidal self-directed violence, but not suicidal ideation, outcomes were included in this report.
6 | Since you did not include studies that were included in the prior Mann review, it would be important and helpful to know (briefly) what the findings were from that review and compare and contrast them—did we learn anything new and what did we learn? | We have added a more comprehensive summary from this Mann report as well as from the Gaynes and NICE 2011 Self-Harm reports.
6 | You should briefly define reclassification analysis. | We have done this in the Summary and Discussion under KQ#1.
6 | In the descriptions in the text of individual studies, I would like to know just a bit more about the design/ structure of the study, in particular overall design (e.g. prospective cohort) and how long patients were followed. At the same time, in the Executive Summary I think you have more detail on the specific studies than you need. | Thank you. We have taken this comment into account in our edits of the main report and also the Executive Summary
6 | In the Executive Summary, I would include the names of the actual measures, not just the abbreviations in the subsections describing studies that used those measures. | We have made this change.
6 | On page 2 of the main document, you say that available evidence suggests that only 4% of people identified as high risk in primary care are truly at risk…--you reference the Gaynes study. To my recollection this 4% figure is the result of an estimate using a best case scenario—you may want to review and restate. | We have provided additional information on the estimates from the Gaynes article; included these because they demonstrate the difficulties with developing assessment tools for rare outcomes.
6 | I think your analytic models are overly detailed (e.g. intake form, specific types of pharmacotherapy or psychotherapy). For me these detract a bit from the overall models and flow and don't add much | We have condensed these into one overall model, and have kept the amount of detail to be consistent with the Suicide Prevention Interventions report.
6 | For KQ2 you write that 2 studies were of limited quality—but which two?—you report that 3 of the studies had methodological flaws with high risk of bias | 4 of the 26 studies identified for KQ2 had high risk of bias and were cited and not reviewed further.
6 | In your recommendations (and perhaps other places earlier) I would suggest you address need for briefer screens (or comment on how long/brief the screens are you recommend for further testing. | We have made this recommendation throughout the report.
Question 5. Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
2 | No. In the absence of a review of instruments that are promising on the basis of studies in the civilian population, the report has limited utility. It should not be used to guide clinical performance measures, programs, quality improvement measures, patient care services, or conferences. | We have updated the report to include a more in depth summary of existing assessment literature on civilian populations from the Mann, Gaynes, NICE 2011, Brown, and Goldston reports.
3 | Would think this would impact current practices. | Noted.
4 | Suicide prevention is quite prominent across many programs in VA and DoD. | Noted.
5 | Indirectly, we will continue to educate stakeholders on the lack of data to support the use of specific risk assessment instruments. | Noted.
6 | VA Office of Mental Health—Suicide Prevention VISN 19 MIRECC Canandaigua Center of Excellence | Noted.
Question 6. Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | It would be helpful for the field to know what are the best available algorithms of suicide risk, and perhaps develop a risk model for clinicians to use to identify patients in their panel at highest risk ) (e.g. through the PACT COMPASS). | We agree that this is an important goal.
1 | In addition, the VA has rolled out the PHQ-9 which includes a question on suicidal ideation- some additional research on its utility in predicting suicide would be helpful. | We have updated the assessment section to include information on the PHQ-9, though we did not find any studies on this assessment tool that met inclusion criteria. We included PHQ-9 in the Discussion.
2 | Address question 3 | We have updated the report to include a more in depth summary of existing assessment literature on civilian populations from the Mann, Gaynes, NICE 2011, Brown, and Goldston reports.
3 | Recommendations re: if and how findings should be incorporated in current practices (e.g., intake) | Recommendations are beyond the scope of this report and will be addressed by the EBPWG.
4 | There is nothing here to implement. | Noted.
5 | The ASI is no longer routinely used in VA substance abuse settings; the report also seems to discuss the importance of use in primary care for some but not all of the instruments. That would be useful to address as a separate section | We have made this correction re: the ASI. We also provide an expanded discussion of screening and assessment tools that could most easily be applied in primary care settings.
7 | Address question 3 | We have updated the report to include a more in depth summary of existing assessment literature on civilian populations from the Mann, Gaynes, NICE 2011, Brown, and Goldston reports.
Question 7. Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | Jan Kemp and Toni Zeiss- OMHS Ira Katz and Mary Schohn- OMHO Gordon Schectman and Rick Stark- Primary Care/ PACT | Noted. We will disseminate the report accordingly.
3 | Mark Ilgen | Noted. We will disseminate the report accordingly.
4 | Office of Research and Development – to help press the need for more research | Noted. We will disseminate the report accordingly.
5 | Quality Managers | Noted. We will disseminate the report accordingly.
6 | Jan Kemp, Ira Katz, Robert Bossarte | Noted. We will disseminate the report accordingly.