# RISK OF BIAS RATINGS FOR PRIMARY STUDIES OF FACTORS TO PREDICT SUICIDAL SELF-DIRECTED VIOLENCE IN MILITARY AND VETERAN POPULATIONS^a^ a Risk of Bias tool modified from Hayden et al. 2006 and Harris et al. 2001.^9, 10^