# RISK OF BIAS RATINGS FOR PRIMARY STUDIES RELATED TO ASSESSING RISK OF ENGAGING IN SUICIDAL SELF-DIRECTED VIOLENCE AMONG MILITARY AND VETERAN POPULATIONS^a^ a Risk of Bias tool modified from Hayden et al. 2006 and Harris et al. 2001.^9, 10^