# SUMMARY AND DISCUSSION

A summary of evidence is provided in Table 12 and strength of evidence ratings for studies of healthcare service interventions for suicide prevention are provided in Table 13.

Table 12 Summary of Evidence

Key Question | | Number/Type of Studies | Risk of Bias and Limitations | Summary of Findings
1A | What are the accuracy and adverse effects of methods tof identify Veterans and military personnel at increased risk for suicide and other suicidal self-directed violence? | - 15 new studies and 4 from the previous ESP review.; - 2 case-control studies, 17 case-series; all were designed to determine diagnostic accuracy.; - 5 studies of Veterans; 1 of active military. | - Risk of bias: 3 studies low; 6 high; 10 unclear.; - Limitations: biased or unclear selection criteria for the study populations; non-standardized risk assessment procedures; inadequate outcome assessments; small sample sizes; high or unclear loss to follow-up; potentially biased participant selection.; - No studies of adverse effects. | - Studies used models derived from databases or clinician-rated or patient self-report instruments.; - Accuracy varied across methods and cut-points; sensitivity ranged from 11% to 100%; AUC from 0.57 to 0.97.; - Method to predict suicide derived from database of >5 million VA patients: AUC 0.761 (95% CI, 0.751 to 0.771).; - Method to predict suicide derived from database of US active military with psychiatric hospitalizations: AUC 0.89.
1B | Does accuracy and adverse effects vary by settings, delivery modes, targeted populations, or other factors? | No studies | Not applicable | Not applicable
2 | What are the efficacy/effectiveness and adverse effects of suicide prevention interventions in reducing rates of suicide and other suicidal self-directed violence in Veterans and military personnel?
2A | Healthcare services directed towards populations. | - 6 before-after studies; 1 post intervention series; 1 retrospective cohort study.; - 2 studies in active US military; 1 study in Canadian police. | - Risk of bias: unclear for the retrospective cohort study; could not be determined for other studies.; - Limitations: inherent biases of ecological studies; confounders not considered; non-comparability of comparison groups; no information on usual care.; - No studies of adverse effects. | - Suicide rates were lower after interventions in 6 studies, including studies of the Air Force Suicide Prevention Program; a program for an Army Infantry Division deployed to Iraq; and studies of police, college students, and health systems.; - Suicide rates were not lower in 2 studies of community programs.
2B | Healthcare services directed towards individuals. | - 5 new RCTs; 5 RCTs from the previous ESP review.; - 1 RCT in active military. | - Risk of bias: high in 5 studies; unclear in 5.; - Most studies were underpowered to detect differences between comparisons.; - Limitations: lack of information on randomization, allocation concealment, blinding, and outcome reporting; unclear or lack of outcome measures.; - No studies of adverse effects. | - Active-duty soldiers with recent suicide attempts/ideation had fewer attempts 2-years after a brief cognitive behavioral therapy program versus usual care (13.8% vs 40.2%, P=.02; hazard ratio 0.38, 95% CI, 0.16 to 0.87).; - Women with borderline personality disorder had fewer suicide attempts one year following dialectical behavior therapy versus usual care (23% vs 46%; P=.01).; - 8 other RCTs indicated no differences between treatment and usual care.

Abbreviations: AUC = area under the receiver-operator characteristic (ROC) curve; CI = confidence interval; ESP = Evidence-based Synthesis Program; RCT = randomized controlled trial.

Table 13 Strength of Evidence Ratings for Studies of the Efficacy/Effectiveness and Adverse Effects of Healthcare Service Interventions for Suicide Prevention

Outcome | Study Design/Number of Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Overall Effect | Strength of Evidence/Grade^*^
Population-level interventions versus none
Suicide attempt | No studies | | | | | | | Insufficient
Suicide | 8 observational (N>5,000,000) | High | Indirect | Unknown | Imprecise | Unknown | Decrease or none | Low
Adverse effects | No studies | | | | | | | Insufficient
Individual-level interventions (psychotherapy) versus usual care
Suicide attempt | 7 RCTs (N=670) | High | Direct | Unknown | Imprecise | Unknown | Decrease or none | Low
Suicide | 4 RCTs (N=1,337) | High | Direct | Unknown | Imprecise | Unknown | Unclear | Insufficient
Adverse effects | No studies | | | | | | | Insufficient

Abbreviations: RCTs = randomized controlled trials.

* Strength of Evidence tool from the Agency for Healthcare Research and Quality’s (AHRQ) Evidence-based Practice Centers (EPC).29. Rating Definitions: Low = Limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). Additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.

Insufficient = No evidence, unable to estimate an effect, or no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1 A. What are the accuracy and adverse effects of methods to identify Veterans and military personnel at increased risk for suicide and other suicidal self-directed violence? B. Does accuracy and adverse effects vary by settings, delivery modes, targeted populations, or other factors?

Fifteen recently published studies and 4 from the previous VA ESP systematic review evaluated the accuracy of methods to identify individuals at risk for suicide and other suicidal self-directed violence and met inclusion criteria for this review. These include 2 case-control studies and 17 case-series studies designed to determine measures of diagnostic accuracy. No studies evaluated the adverse effects of risk assessment methods, or compared how accuracy and adverse effects vary by settings, delivery modes, targeted populations, or other factors.

Results of studies indicated estimates of sensitivity ranging from 11% to 100% and AUC from 0.57 to 0.97. Several risk assessment methods had estimates of sensitivity ≥80% or AUC ≥0.70, suggesting fair or better discrimination between patients with and without suicides or suicide attempts. Several studies used data from electronic medical records or administrative databases to identify individuals with known risk factors for suicide. The most relevant study used data from nearly 6 million patients of the VA to create a prediction model to stratify patients according to their risk for suicide within the next year. This method had an AUC of 0.761 (95% CI, 0.751 to 0.771).

Four additional studies of Veterans were included in the previous VA ESP review. In one study, a decision tree for identifying high-risk patients was derived from the Addiction Severity Index and variables from VA databases. Sensitivity/specificity varied across the 3 prediction models that were evaluated (33%/87%, 72%/63%, 89%/42%). Three studies of Veterans evaluated the accuracy of established instruments to predict suicidal attempts and suicide. Results indicated high sensitivity/specificity for the Suicide Potential Index (91%/77%), and lower estimates for the Beck Depression Inventory (63%/80%) and Affective States Questionnaire (60%/74%).

The only study of military personnel was based on Army STARRS and included 40,820 active duty US Army soldiers hospitalized with psychiatric admission diagnoses. A risk algorithm to predict suicides within one year of hospitalization was developed from administrative data systems and demonstrated AUCs as high as 0.89.

Additional studies of non-Veterans evaluated the diagnostic accuracy of the risk instruments, including the Affective Intensity Rating Scale, Barwon Health Suicide Risk Assessment, Death/suicide Implicit Association Test, SAD PERSONS, Schedule for Nonadaptive and Adaptive Personality, Suicide Opinion Questionnaire, Sleep Quality Index, Suicidal Ideation Attributes Scale, and Suicide Trigger Scale. Results indicated a wide range of estimates depending on the instrument and selected cut-points.

Current conventions do not provide strength of evidence grades for diagnostic accuracy studies. Studies of methods of risk assessment that were derived from large databases provided a rigorous approach with low risk of bias and high clinical applicability. Results indicated fair or better diagnostic accuracy for some of the models. These methods should be replicated in additional patient populations to refine the data variables and optimal cut-points, and further validate findings before they are adapted to clinical care uses.

Studies based on the diagnostic accuracy of individual instruments and scales are also useful, but are currently limited by small sample sizes, methodological limitations, and unclear applicability. Risk assessment instruments may provide diagnostic value to specific patient subgroups, such as those with previous suicide attempts or co-existing conditions. However, the current evidence base includes numerous inconclusive, small studies of a variety of instruments. Instruments demonstrating fair to good diagnostic accuracy in these studies should be further tested in larger clinical populations.

### Key Question 2 What are the efficacy/effectiveness and adverse effects of suicide prevention interventions in reducing rates of suicide and other suicidal self-directed violence in Veterans and military personnel? Interventions include healthcare services directed towards A) populations and B) individuals

#### Population-level Healthcare Interventions

Eight studies of the efficacy or effectiveness of population-level healthcare interventions met inclusion criteria, including a follow-up analysis of a study that was included in the previous VA ESP review. These studies evaluated multi-component initiatives implemented within existing organizational structures that included military populations, police officers, college students, and healthcare systems. One study was designed as a retrospective cohort study, 5 were before-after studies, one was an ecological comparison study, and one was a post intervention series. All interventions except for one were designed for primary prevention of suicide. No studies evaluated adverse effects of population-level interventions.

Three studies evaluated interventions in military personnel or police officers. An initial before-after study of the Air Force Suicide Prevention Program, an Air Force-wide intervention that included policy and education initiatives, found that implementation of the program was associated with reduced risk for suicide in over 5 million active duty US Air Force personnel. Long-term follow-up also indicated reduced suicide rates after implementation. A program in an Army Infantry Division deployed to Iraq also resulted in lower suicide rates for the intervention unit compared with rates for service members in theater and for the US Army specifically, although statistical comparisons were not provided. Suicide rates were statistically significantly lower after implementation of a suicide prevention program among police officers in Montreal.

Additional studies evaluated population-level interventions implemented in healthcare and other settings. Suicide rates were reduced in studies of the Perfect Depression Care initiative in a large health maintenance organization in the US; implementation of service recommendations in England and Wales; and after a mandated secondary prevention program for college students in a US university. No reductions were found in a study of the long-term impact of specialized early psychosis treatment on suicidal behaviors in Australia, and among adults in a community program in the US.

The strength of evidence grades for population-level healthcare interventions are insufficient for suicide attempt outcomes (no studies), low for suicide outcomes (8 observational studies), and insufficient for adverse effects (no studies). The low strength of evidence grade for suicide outcomes indicates that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect. Although 6 of the 8 studies of interventions suggested reductions in suicide rates, the interventions varied across studies, risk of bias was unclear, and the comparability of comparison groups was not established. While the studies provided promising initial findings, these interventions should be replicated under more controlled conditions, such as in RCTs, to strengthen the evidence of their effectiveness.

#### Individual-level Healthcare Interventions

Five recently published RCTs and 5 trials from the previous VA ESP review met inclusion criteria. No studies evaluated adverse effects of interventions. Trials compared usual care to individual psychotherapies, including cognitive behavioral therapy, dialectical behavior therapy, personal construct psychotherapy, problem-solving therapy or skills training, and day hospital treatment. Trials enrolled outpatient military personnel and non-military psychiatric inpatients or patients at acute risk for suicide. No studies enrolled Veterans specifically and no studies evaluated the adverse effects of individual-level interventions.

Only 2 trials reported statistically significant differences between treatment and usual care. In one trial, outpatient active duty soldiers with recent suicide attempts or ideation in a brief cognitive behavioral therapy program were less likely to make suicide attempts at 2 years follow-up than those in usual care. In a trial of women with borderline personality disorder, those receiving dialectical behavior therapy had fewer suicide attempts compared with those receiving usual care at one year follow-up.

The strength of evidence grades for individual-level healthcare interventions are low for suicide attempt outcomes (7 trials), insufficient for suicide outcomes (4 trials), and insufficient for adverse effects (no studies). The low strength of evidence grade for suicide attempt outcomes indicates that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect. The most relevant trial, comparing brief outpatient cognitive behavioral therapy versus usual care in Army soldiers, indicated statistically significantly reduced suicide attempts for the intervention group, although its risk of bias was unclear. These findings support cognitive behavioral therapy as a suicide prevention intervention and are consistent with other trials of cognitive behavioral therapy in various population groups and settings that did not meet inclusion criteria for this review.15,16 Larger trials of similar therapies in Veteran and military populations would build on this work and strengthen the evidence base.

The insufficient strength of evidence grade for suicide outcomes indicates that the body of evidence has unacceptable deficiencies that preclude deriving conclusions. In this case, the 4 trials reporting suicide outcomes had too few participants and suicide events to determine statistically significant differences between treatment and usual care. These interventions require replication in larger trials that are sufficiently powered to detect differences in order to determine their effectiveness in suicide prevention.

## LIMITATIONS

### Study Quality

For studies of risk assessment, risk of bias was rated low in 3 studies, high in 6, and unclear in 10. Limitations of studies with high or unclear risk of bias included biased or unclear selection criteria for the study populations; non-standardized risk assessment procedures; inadequate outcome assessments; small sample sizes; and high or unclear loss to follow-up.

Risk of bias for studies of population-level interventions was unclear for the retrospective cohort study, and could not be determined for other studies because of the lack of risk of bias criteria for these study designs. Limitations of studies included inadequate consideration of potential confounders, non-comparability of comparison groups, and lack of information on usual care.

Risk of bias for trials of individual-level interventions was rated high in 5 trials and unclear in 5. Most studies were underpowered to detect differences between treatment and usual care. Limitations of studies included lack of information on randomization, allocation concealment, blinding, and outcome reporting; and unclear or lack of specified outcome measures.

### Heterogeneity

Studies were highly heterogeneous for both the risk assessment and prevention intervention key questions included in this review. Specific risk assessment methods and prevention interventions were rarely examined in more than one study, precluding statistical meta-analysis of results and limiting applicability to clinical practice. In addition, studies were generally conducted in small, specialized populations that may yield unique results. Future research to reduce heterogeneity will improve the evidence base, such as a recent effort by the National Institutes of Health, VA, and Department of Defense to define common data elements for suicide prevention research.184

### Applicability of Findings to the VA Population

Of the 37 studies included in this review (including 9 from previous VA ESP reviews), 5 studies of risk assessment included Veterans and one included active military personnel, and 3 studies of interventions included active military personnel. In addition, inclusion criteria for studies enrolling participants outside Veterans and military populations focused on participants with similar demographic characteristics. While these criteria may have excluded important studies, they also improved the systematic review’s clinical relevance to the VA population.

## CONCLUSIONS

Studies of risk assessment methods to identify individuals at increased risk for suicide and other suicidal self-directed violence evaluated numerous different approaches. Methods derived from data from electronic medical records, including studies of Veterans and military personnel, were robust predictors of subsequent suicide. Studies of various clinician-rated or patient self-report risk assessment instruments indicated accuracy that varied across methods and cut-points. Studies of multi-component population-level suicide prevention interventions and individual cognitive behavioral therapy in military populations showed reduced suicide attempts and suicide. However, evidence is limited by the many single, inconclusive studies of various risk assessment instruments and prevention interventions, methodological deficiencies of studies, inherent challenges in conducting research in this area, and lack of studies addressing adverse effects.