# REFERENCES

1 Shekelle P, Bagley S, Munjas B. Strategies for Suicide Prevention in Veterans. Department of Veterans Affairs. 2009. http://www.ncbi.nlm.nih.gov/books/NBK49132/. [pmid: 21155206]. Accessed September 25, 2015.
2 Haney E, O’Neil M, Carson S, et al. Suicide Risk Factors and Risk Assessment Tools: A Systematic Review. Washington, D.C. Department of Veterans Affairs. 2012. http://www.hsrd.research.va.gov/publications/esp/suicide-risk.cfm. [pmid: 22574340]. Accessed September 25, 2015.
3 O’Neil M, Peterson K, Low A, et al. Suicide Prevention Interventions and Referral/Follow-Up Services: A Systematic Review. Washington, D.C. Department of Veterans Affairs. 2012. http://www.hsrd.research.va.gov/publications/esp/suicide-interventions.cfm. [pmid: 22574339]. Accessed September 25, 2015.
4 Parks SE, Johnson LL, McDaniel DD, Gladden M. Surveillance for violent deaths - National Violent Death Reporting System, 16 states, 2010. MMWR Surveill Summ. Jan. 17. 2014;63(1):1-33. [pmid: 24430165].
5 Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. National Violent Death Reporting System: Monitoring and Tracking the Causes of Violent Deaths - 2008. 2008. http://stacks.cdc.gov/view/cdc/11530/. Accessed October 21, 2015.
6 Schoenbaum M, Kessler RC, Gilman SE, et al. Predictors of suicide and accident death in the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS): results from the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS). JAMA Psychiatry. 2014;71(5):493-503. [pmid: 24590048].
7 Denneson LM, Teo AR, Ganzini L, Helmer DA, Bair MJ, Dobscha SK. Military Veterans’ Experiences with Suicidal Ideation: Implications for Intervention and Prevention. Suicide Life Threat Behav. 2015;45(4):399-414. [pmid: 25367753].
8 Hoffmire C, Kemp J, Bossarte R. Changes in Suicide Mortality for Veterans and Nonveterans by Gender and History of VHA Service Use, 2000–2010. Psychiatr Serv. 2015;66(9):959-965. [pmid: 25930036].
9 Ursano RJ, Colpe LJ, Heeringa SG, et al. The Army study to assess risk and resilience in servicemembers (Army STARRS). Psychiatry. 2014;77(2):107-119. [pmid: 24865195].
10 Nock MK, Stein MB, Heeringa SG, et al. Prevalence and correlates of suicidal behavior among soldiers: results from the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS). JAMA Psychiatry. 2014;71(5):514-522. [pmid: 24590178].
11 Ursano RJ, Heeringa SG, Stein MB, et al. Prevalence and correlates of suicidal behavior among new soldiers in the U.S. Army: results from the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS). Depress Anxiety. Jan. 2015;32(1):3-12. [pmid: 25338964].
12 Luoma JB, Martin CE, Pearson JL. Contact with mental health and primary care providers before suicide: a review of the evidence. Am J Psychiatry. Jun. 2002;159(6):909-916. [pmid: 12042175].
13 Dobscha SK, Denneson LM, Kovas AE, et al. Correlates of suicide among veterans treated in primary care: case-control study of a nationally representative sample. J Gen Intern Med. 2014;29(Suppl 4):853-860. [pmid: 25355088].
14 LeFevre ML. Screening for suicide risk in adolescents, adults, and older adults in primary care: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. May. 20. 2014;160(10):719-726. [pmid: 24842417].
15 O’Connor E, Gaynes BN, Burda BU, Soh C, Whitlock EP. Screening for and treatment of suicide risk relevant to primary care: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013;158(10):741-754. [pmid: 23609101].
16 O’Connor E, Gaynes B, Burda BU, Williams C, Whitlock EP. Screening for suicide risk in primary care: a systematic evidence review for the US Preventive Services Task Force. Agency for Healthcare Research and Quality (AHRQ). 2013.
17 U. S. Preventive Services Task Force. Screening for depression in adults: U.S. preventive services task force recommendation statement. Ann Intern Med. Dec. 1. 2009;151(11):784-792. [pmid: 19949144].
18 Moyer VA. Preventive Services Task F. Screening and behavioral counseling interventions in primary care to reduce alcohol misuse: U.S. preventive services task force recommendation statement. [Summary for patients in Ann Intern Med. 2013 Aug 6;159(3):I-32; PMID: 23698731]. Ann Intern Med. Aug. 6. 2013;159(3):210-218. [pmid: 23698791].
19 Moyer VA. Force USPST. Screening for intimate partner violence and abuse of elderly and vulnerable adults: U.S. preventive services task force recommendation statement. [Summary for patients in Ann Intern Med. 2013 Mar 19;158(6):I-28; PMID: 23338797]. Ann Intern Med. Mar. 19. 2013;158(6):478-486. [pmid: 23338828].
20 The Assessment and Management of Risk for Suicide Working Group. VA/DoD Clinical Practice Guideline for Assessment and Management of Patients at Risk for Suicide. Washington (DC). Department of Veterans Affairs, Department of Defense. 2013.
21 Nelson H, Low A, Denneson L, Teo A, O’Neil M, Kansagara D. Systematic review of suicide prevention in U.S. military veterans. PROSPERO: CRD42015019089. 2015. http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42015019089.
22 Nelson H. Systematic reviews to answer health care questions. Philadelphia Wolters Kluwer Health. 2014.
23 Crosby A, Ortega L, Melanson C. Self-directed Violence Surveillance: Uniform Definitions and Recommended Data Elements, Version 1.0. Atlanta (GA). Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 2011.
24 Department of Veterans Affairs. Memorandum re: Standardized Suicide Nomenclature (Self-Directed Violence Classification System). Washington, DC. US Government Printing Office. 2010.
25 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. Cochrane Collaboration. 2011. www.cochrane-handbook.org. Accessed October 21, 2015.
26 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
27 Agency for Healthcare Research and Quality. U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. 2008. http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. Accessed October 12, 2015.
28 Hayden JA, Cote P, Bombardier C. Evaluation of the quality of prognosis studies in systematic reviews. Ann Intern Med. 2006;144(6):427-437. [pmid: 16549855].
29 Berkman N, Lohr K, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Rockville, MD. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews (AHRQ Publication No. 13(14)-EHC130-EF). 2013.
30 Batterham PJ, Ftanou M, Pirkis J, et al. A Systematic Review and Evaluation of Measures for Suicidal Ideation and Behaviors in Population-Based Research. Psychol Assess. 2015;27(2):501-512. [pmid: 25496086].
31 Mann JJ, Apter A, Bertolote J, et al. Suicide prevention strategies: a systematic review. JAMA. 2005;294(16):2064-2074. [pmid: 16249421].
32 Gaynes BN, West SL, Ford CA, et al. Screening for suicide risk in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(10):822-835. [pmid: 15148072].
33 Breshears RE, Brenner LA, Harwood JE, Gutierrez PM. Predicting suicidal behavior in veterans with traumatic brain injury: the utility of the personality assessment inventory. J Pers Assess. 2010;92(4):349-355. [pmid: 20552509].
34 Hartl TL, Rosen C, Drescher K, Lee TT, Gusman F. Predicting high-risk behaviors in veterans with posttraumatic stress disorder. J Nerv Ment Dis. 2005;193(7):464-472. [pmid: 15985841].
35 Hendin H, Al Jurdi RK, Houck PR, Hughes S, Turner JB. Role of intense affects in predicting short-term risk for suicidal behavior: a prospective study. J Nerv Ment Dis. 2010;198(3):220-225. [pmid: 20216000].
36 Tiet QQ, Ilgen MA, Byrnes HF, Moos RH. Suicide attempts among substance use disorder patients: an initial step toward a decision tree for suicide management. Alcoholism: Clinical & Experimental Research. 2006;30(6):998-1005.
37 Crawford MJ, Thana L, Methuen C, et al. Impact of screening for risk of suicide: randomised controlled trial. Br J Psychiatry. May. 2011;198(5):379-384. [pmid: 21525521].
38 Bernert RA, Turvey CL, Conwell Y, Joiner TE Jr. Association of poor subjective sleep quality with risk for death by suicide during a 10-year period: a longitudinal, population-based study of late life. JAMA Psychiatry. 2014;71(10):1129-1137. [pmid: 25133759].
39 Bolton JM, Spiwak R, Sareen J. Predicting suicide attempts with the SAD PERSONS scale: a longitudinal analysis. J Clin Psychiatry. 2012;73(6):e735-741. [pmid: 22795212].
40 Galfalvy HC, Oquendo MA, Mann JJ. Evaluation of clinical prognostic models for suicide attempts after a major depressive episode. Acta Psychiatr Scand. 2008;117(4):244-252. [pmid: 18321353].
41 Galynker I, Yaseen ZS, Briggs J, Hayashi F. Attitudes of acceptability and lack of condemnation toward suicide may be predictive of post-discharge suicide attempts. BMC Psychiatry. 2015;15:87. [pmid: 25884153].
42 Kessler RC, Warner CH, Ivany C, et al. Predicting suicides after psychiatric hospitalization in US Army soldiers: the Army Study To Assess Risk and rEsilience in Servicemembers (Army STARRS). JAMA Psychiatry. 2015;72(1):49-57. [pmid: 25390793].
43 McCarthy JF, Bossarte RM, Katz IR, et al. Predictive Modeling and Concentration of the Risk of Suicide: Implications for Preventive Interventions in the US Department of Veterans Affairs. Am J Public Health. ePub ahead of print June 11, 2015. 2015:e1-5.
44 Nock MK, Park JM, Finn CT, Deliberto TL, Dour HJ, Banaji MR. Measuring the suicidal mind: implicit cognition predicts suicidal behavior. Psychol Sci. 2010;21(4):511-517. [pmid: 20424092].
45 Rana S, Gupta S, Venkatesh S, et al. An Analysis of Suicide Risk Assessment. Pattern Recognition and Data Analytics, Report Number: TR-PRaDA-03/12. 2012.
46 Steeg S, Kapur N, Webb R, et al. The development of a population-level clinical screening tool for self-harm repetition and suicide: the ReACT Self-Harm Rule. Psychol Med. 2012;42(11):2383-2394. [pmid: 22394511].
47 Tran T, Luo W, Phung D, et al. Risk stratification using data from electronic medical records better predicts suicide risks than clinician assessments. BMC Psychiatry. 2014;14:76. [pmid: 24628849].
48 van Spijker BA, Batterham PJ, Calear AL, et al. The suicidal ideation attributes scale (SIDAS): Community-based validation study of a new scale for the measurement of suicidal ideation. Suicide Life Threat Behav. 2014;44(4):408-419. [pmid: 24612048].
49 Yaseen ZS, Fisher K, Morales E, Galynker II. Love and suicide: the structure of the Affective Intensity Rating Scale (AIRS) and its relation to suicidal behavior. PLoS One. 2012;7(8):e44069. [pmid: 22952877].
50 Yaseen ZS, Gilmer E, Modi J, Cohen LJ, Galynker II. Emergency room validation of the revised Suicide Trigger Scale (STS-3): a measure of a hypothesized suicide trigger state. PLoS One. 2012;7(9):e45157. [pmid: 23024805].
51 Yaseen ZS, Kopeykina I, Gutkovich Z, Bassirnia A, Cohen LJ, Galynker II. Predictive validity of the Suicide Trigger Scale (STS-3) for post-discharge suicide attempt in high-risk psychiatric inpatients. PLoS One. 2014;9(1):e86768. [pmid: 24466229].
52 Yen S, Shea MT, Walsh Z, et al. Self-harm subscale of the Schedule for Nonadaptive and Adaptive Personality (SNAP): predicting suicide attempts over 8 years of follow-up. J Clin Psychiatry. 2011;72(11):1522-1528. [pmid: 21294991].
53 McLellan AT, Kushner H, Metzger D, et al. The Fifth Edition of the Addiction Severity Index. J Subst Abuse Treat. 1992;9(3):199-213. [pmid: 1334156].
54 Hendin H, Maltsberger JT, Szanto K. The role of intense affective states in signaling a suicide crisis. J Nerv Ment Dis. May. 2007;195(5):363-368. [pmid: 17502800].
55 Hendin H, Maltsberger JT, Haas AP, Szanto K, Rabinowicz H. Desperation and other affective states in suicidal patients. Suicide Life Threat Behav. 2004;34(4):386-394. [pmid: 15585460].
56 Barwon Health. Suicide Risk Assessment. Barwon Health. 1999. http://www.barwonhealth.org.au/suicideriskassesment. Accessed October 2, 2015.
57 Beck AT, ASR, KBG. Beck Depression Inventory--II. 1996.
58 Posner K, Oquendo MA, Gould M, Stanley B, Davies M. Columbia Classification Algorithm of Suicide Assessment (C-CASA): classification of suicidal events in the FDA’s pediatric suicidal risk analysis of antidepressants. Am J Psychiatry. Jul. 2007;164(7):1035-1043. [pmid: 17606655].
59 Posner K, Brown GK, Stanley B, et al. The Columbia-Suicide Severity Rating Scale: initial validity and internal consistency findings from three multisite studies with adolescents and adults. Am J Psychiatry. 2011;168(12):1266-1277. [pmid: 22193671].
60 Greenwald AG, McGhee DE, Schwartz JL. Measuring individual differences in implicit cognition: the implicit association test. J Pers Soc Psychol. Jun. 1998;74(6):1464-1480. [pmid: 9654756].
61 Keller MB, Lavori PW, Friedman B, et al. The Longitudinal Interval Follow-up Evaluation. A comprehensive method for assessing outcome in prospective longitudinal studies. Arch Gen Psychiatry. Jun. 1987;44(6):540-548. [pmid: 3579500].
62 Hockberger RS, Rothstein RJ. Assessment of suicide potential by nonpsychiatrists using the SAD PERSONS score. J Emerg Med. Mar–Apr. 1988;6(2):99-107. [pmid: 3290325].
63 Morey L. Personality Assessment Inventory (PAI): Professional manual. 2nd ed. Odessa, FL. Psychological Assessment Resources. 2007.
64 Patterson WM, Dohn HH, Bird J, Patterson GA. Evaluation of suicidal patients: the SAD PERSONS scale. Psychosomatics. Apr. 1983;24(4):343-345. 348. 349. [pmid: 6867245].
65 Nock MK, Holmberg EB, Photos VI, Michel BD. Self-Injurious Thoughts and Behaviors Interview: development, reliability, and validity in an adolescent sample. Psychol Assess. Sep. 2007;19(3):309-317. [pmid: 17845122].
66 Clark L. Manual for the Schedule for Nonadaptive and Adaptive Personality. Minneapolis, MN. University of Minnesota Press. 1993.
67 Domino G. Test-retest reliability of the Suicide Opinion Questionnaire. Psychol Rep. Jun. 1996;78(3 Pt 1):1009-1010. [pmid: 8711019].
68 Domino G, Moore D, Westlake L, Gibson L. Attitudes toward suicide: a factor analytic approach. J Clin Psychol. Apr. 1982;38(2):257-262. [pmid: 7068859].
69 Cornoni-Huntley J, Ostfeld AM, Taylor JO, et al. Established populations for epidemiologic studies of the elderly: study design and methodology. Aging-Clinical & Experimental Research. Feb. 1993;5(1):27-37.
70 Oquendo MA, Galfalvy H, Russo S, et al. Prospective study of clinical predictors of suicidal acts after a major depressive episode in patients with major depressive disorder or bipolar disorder. Am J Psychiatry. Aug. 2004;161(8):1433-1441. [pmid: 15285970].
71 Bergen H, Hawton K, Waters K, Cooper J, Kapur N. Epidemiology and trends in non-fatal self-harm in three centres in England: 2000–2007. Br J Psychiatry. Dec. 2010;197(6):493-498. [pmid: 21119156].
72 Comtois KA, Jobes DA, Atkins DC, et al. Collaborative assessment and management of suicidality (CAMS): Feasibility trial for next-day appointment services. Depress Anxiety. 2011;28(11):963-972. [pmid: 21948348].
73 Gallo JJ, Bogner HR, Morales KH, Post EP, Lin JY, Bruce ML. The effect of a primary care practice-based depression intervention on mortality in older adults: a randomized trial. [Summary for patients in Ann Intern Med. 2007 May 15;146(10):I38; PMID: 17502628]. Ann Intern Med. 2007;146(10):689-698. [pmid: 17502629].
74 Knox KL, Litts DA, Talcott GW, Feig JC, Caine ED. Risk of suicide and related adverse outcomes after exposure to a suicide prevention programme in the US Air Force: cohort study. BMJ. 2003;327(7428):1376. [pmid: 14670880].
75 Linehan MM, Comtois KA, Murray AM, et al. Two-year randomized controlled trial and follow-up of dialectical behavior therapy vs therapy by experts for suicidal behaviors and borderline personality disorder. [Erratum appears in Arch Gen Psychiatry. 2007 Dec;64(12):1401]. Arch Gen Psychiatry. 2006;63(7):757-766. [pmid: 16818865].
76 Stewart CD, Quinn A, Plever S, Emmerson B. Comparing cognitive behavior therapy, problem solving therapy, and treatment as usual in a high risk population. Suicide Life Threat Behav. 2009;39(5):538-547. [pmid: 19929153].
77 Winter D, Sireling L, Riley T, Metcalfe C, Quaite A, Bhandari S. A controlled trial of personal construct psychotherapy for deliberate self-harm. Psychology & Psychotherapy: Theory, Research & Practice. 2007;80(Pt 1):23-37.
78 Knox KL, Pflanz S, Talcott GW, et al. The US Air Force suicide prevention program: Implications for public health policy. Am J Public Health. 2010;100(12):2457-2463. [pmid: 20466973].
79 Coffey CE. Building a system of perfect depression care in behavioral health. Joint Commission Journal on Quality & Patient Safety. 2007;33(4):193-199. [pmid: 17441556].
80 Harris MG, Burgess PM, Chant DC, Pirkis JE, McGorry PD. Impact of a specialized early psychosis treatment programme on suicide. Retrospective cohort study. Early Interv Psychiatry. 2008;2(1):11-21. [pmid: 21352126].
81 Warner CH, Appenzeller GN, Parker JR, Warner C, Diebold CJ, Grieger T. Suicide prevention in a deployed military unit. Psychiatry: Interpersonal and Biological Processes. 2011;74(2):127-141.
82 Joffe P. An empirically supported program to prevent suicide in a college student population. Suicide Life Threat Behav. 2008;38(1):87-103. [pmid: 18355111].
83 Mishara BL, Martin N. Effects of a comprehensive police suicide prevention program. Crisis. 2012;33(3):162-168. [pmid: 22450038].
84 Walrath C, Garraza LG, Reid H, Goldston DB, McKeon R. Impact of the Garrett Lee Smith youth suicide prevention program on suicide mortality. Am J Public Health. 2015;105(5):986-993. [pmid: 25790418].
85 While D, Bickley H, Roscoe A, et al. Implementation of mental health service recommendations in England and Wales and suicide rates, 1997–2006: a cross-sectional and before-and-after observational study. Lancet. 2012;379(9820):1005-1012. [pmid: 22305767].
86 Institute of Medicine. Report Brief. Crossing the Quality Chasm: A New Health System for the 21st Century. 2001. http://iom.nationalacademies.org/reports/2001/crossing-the-quality-chasm-a-new-health-system-for-the-21st-century.aspx. Accessed September 15, 2015.
87 Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington DC. National Academy Press. 2001.
88 McGorry PD, Edwards J, Mihalopoulos C, Harrigan SM, Jackson HJ. EPPIC: an evolving system of early detection and optimal management. Schizophr Bull. 1996;22(2):305-326. [pmid: 8782288].
89 Appleby L, Shaw J, Sherratt J, Amos T, Robinson J, McDonnell R. Safety first: five-year report of the National Confidential Inquiry into suicide and homicide by people with mental illness. London. Stationery Office. 2001.
90 Goldston DB, Walrath CM, McKeon R, et al. The Garrett Lee Smith memorial suicide prevention program. Suicide Life Threat Behav. Jun. 2010;40(3):245-256. [pmid: 20560746].
91 Jones G, Gavrilovic JJ, McCabe R, Becktas C, Priebe S. Treating suicidal patients in an acute psychiatric day hospital: A challenge to assumptions about risk and overnight care. J Ment Health. 2008;17(4):375-387.
92 McAuliffe C, McLeavey BC, Fitzgerald T, et al. Group problem-solving skills training for self-harm: Randomised controlled trial. Br J Psychiatry. 2014;204(5):383-390. [pmid: 24434070].
93 Rudd MD, Bryan CJ, Wertenberger EG, et al. Brief cognitive-behavioral therapy effects on post-treatment suicide attempts in a military sample: results of a randomized clinical trial with 2-year follow-up. Am J Psychiatry. 2015;172(5):441-449. [pmid: 25677353].
94 Linehan MM, Korslund KE, Harned MS, et al. Dialectical behavior therapy for high suicide risk in individuals with borderline personality disorder: A randomized clinical trial and component analysis. JAMA Psychiatry. 2015;72(5):475-482. [pmid: 25806661].
95 McMain SF, Guimond T, Streiner DL, Cardish RJ, Links PS. Dialectical behavior therapy compared with general psychiatric management for borderline personality disorder: clinical outcomes and functioning over a 2-year follow-up. Am J Psychiatry. 2012;169(6):650-661. [pmid: 22581157].
96 Linehan MM, Comtois KA, Brown MZ, Heard HL, Wagner A. Suicide Attempt Self-Injury Interview (SASII): development, reliability, and validity of a scale to assess suicide attempts and intentional self-injury. Psychol Assess. Sep. 2006;18(3):303-312. [pmid: 16953733].
97 Linehan M, Comtois K. Lifetime Parasuicide History, Available Department of Psychology. Seattle, WA. University of Washington. 1996.
98 Alexopoulos GS, Reynolds CF 3rd, Bruce ML, et al. Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry. 2009;166(8):882-890. [pmid: 19528195].
99 McMain SF, Links PS, Gnam WH, et al. A randomized trial of dialectical behavior therapy versus general psychiatric management for borderline personality disorder. Am J Psychiatry. 2009;166(12):1365-1374. [pmid: 19755574].
100 Bryan CJ, David Rudd M, Wertenberger E, et al. Improving the detection and prediction of suicidal behavior among military personnel by measuring suicidal beliefs: an evaluation of the Suicide Cognitions Scale. J Affect Disord. 2014;159:15-22. [pmid: 24679384].
101 Randall JR, Rowe BH, Colman I. Emergency department assessment of self-harm risk using psychometric questionnaires. Can J Psychiatry. 2012;57(1):21-28. [pmid: 22296964].
102 Blasco-Fontecilla H, Delgado-Gomez D, Legido-Gil T, de Leon J, Perez-Rodriguez MM, Baca-Garcia E. Can the Holmes-Rahe Social Readjustment Rating Scale (SRRS) be used as a suicide risk scale? An exploratory study. Arch Suicide Res. 2012;16(1):13-28. [pmid: 22289025].
103 Innamorati M, Pompili M, Serafini G, et al. Psychometric properties of the suicidal history self-rating screening scale. Arch Suicide Res. 2011;15(1):87-92. [pmid: 21294003].
104 Fountoulakis KN, Pantoula E, Siamouli M, et al. Development of the Risk Assessment Suicidality Scale (RASS): a population-based study. J Affect Disord. 2012;138(3):449-457. [pmid: 22301115].
105 Mundt JC, Greist JH, Jefferson JW, Federico M, Mann JJ, Posner K. Prediction of suicidal behavior in clinical research by lifetime suicidal ideation and behavior ascertained by the electronic Columbia-Suicide Severity Rating Scale. J Clin Psychiatry. Sep. 2013;74(9):887-893. [pmid: 24107762].
106 Joiner TE, Gutierrez PM. Toward a Gold Standard for Suicide Risk Assessment for Military Personnel. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/toward-gold-standard-suicide-risk-assessment-military-personnel. Accessed September 28, 2015.
107 Baca-Garcia E, Perez-Rodriguez MM, Oquendo MA, et al. Estimating risk for suicide attempt: are we asking the right questions? Passive suicidal ideation as a marker for suicidal behavior. J Affect Disord. 2011;134(1–3):327-332. [pmid: 21784532].
108 Ilgen MA, Downing K, Zivin K, et al. Exploratory data mining analysis identifying subgroups of patients with depression who are at high risk for suicide. J Clin Psychiatry. 2009;70(11):1495-1500. [pmid: 20031094].
109 Poulin C, Shiner B, Thompson P, et al. Predicting the risk of suicide by analyzing the text of clinical notes. PLoS One. Jan. 2014;9(1).
110 Holm-Denoma J, Witte T. A Taxometric Study of Suicide Risk. 2015. https://msrc.fsu.edu/sites/msrc.fsu.edu/files//MSRC_Taxometric_Study_of_Suicide_Risk_Drs_Holm-Denoma_Witte.pdf. Accessed October 15, 2015.
111 Simon GE, Rutter CM, Peterson D, et al. Does response on the PHQ-9 Depression Questionnaire predict subsequent suicide attempt or suicide death?. Psychiatr Serv. 2013;64(12):1195-1202. [pmid: 24036589].
112 LeardMann CA, Powell TM, Smith TC, et al. Risk factors associated with suicide in current and former US military personnel. JAMA. 2013;310(5):496-506. [pmid: 23925620].
113 Nock M. Looking for Cognitive Differences in Suicidal Veterans. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/looking-cognitive-differences-suicidal-veterans. Accessed October 2, 2015.
114 Anestis M. Predicting Suicide Risk in a Military Population. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/predicting-suicide-risk-military-population. Accessed September 30, 2015.
115 Hazlett E, Goodman M. Affective Startle Assessment in High Risk Suicidal Veterans (DoD Supplement). VISN 3 Mental Illness Research, Education & Clinical Center. http://www.mirecc.va.gov/visn3/clinical.asp#Startle. Accessed September 30, 2015.
116 McGirr A, Dombrovski AY, Butters MA, Clark L, Szanto K. Deterministic learning and attempted suicide among older depressed individuals: cognitive assessment using the Wisconsin Card Sorting Task. J Psychiatr Res. 2012;46(2):226-232. [pmid: 22024486].
117 Richard-Devantoy S, Jollant F, Kefi Z, et al. Deficit of cognitive inhibition in depressed elderly: a neurocognitive marker of suicidal risk. J Affect Disord. 2012;140(2):193-199. [pmid: 22464009].
118 Cha CB, Najmi S, Park JM, Finn CT, Nock MK. Attentional bias toward suicide-related stimuli predicts suicidal behavior. J Abnorm Psychol. 2010;119(3):616-622. [pmid: 20677851].
119 Galfalvy H, Huang YY, Oquendo MA, Currier D, Mann JJ. Increased risk of suicide attempt in mood disorders and TPH1 genotype. J Affect Disord. 2009;115(3):331-338. [pmid: 18977032].
120 Kim YK, Hwang JA, Lee HJ, et al. Association between norepinephrine transporter gene (SLC6A2) polymorphisms and suicide in patients with major depressive disorder. J Affect Disord. 2014;158:127-132. [pmid: 24655776].
121 Shinozaki G, Romanowicz M, Passov V, Rundell J, Mrazek D, Kung S. State dependent gene-environment interaction: serotonin transporter gene-child abuse interaction associated with suicide attempt history among depressed psychiatric inpatients. J Affect Disord. 2013;147(1–3):373-378. [pmid: 23261136].
122 Sokolowski M, Ben-Efraim YJ, Wasserman J, Wasserman D. Glutamatergic GRIN2B and polyaminergic ODC1 genes in suicide attempts: associations and gene-environment interactions with childhood/adolescent physical assault. Mol Psychiatry. 2013;18(9):985-992. [pmid: 22850629].
123 Sunnqvist C, Westrin A, Traskman-Bendz L. Suicide attempters: biological stressmarkers and adverse life events. Eur Arch Psychiatry Clin Neurosci. 2008;258(8):456-462. [pmid: 18574612].
124 Jokinen J, Ouda J, Nordstrom P. Noradrenergic function and HPA axis dysregulation in suicidal behaviour. Psychoneuroendocrinology. 2010;35(10):1536-1542. [pmid: 20576361].
125 Brundin L, Bjorkqvist M, Traskman-Bendz L, Petersen A. Increased orexin levels in the cerebrospinal fluid the first year after a suicide attempt. J Affect Disord. 2009;113(1–2):179-182. [pmid: 18533274].
126 Guintivano J, Brown T, Newcomer A, et al. Identification and replication of a combined epigenetic and genetic biomarker predicting suicide and suicidal behaviors. Am J Psychiatry. 2014;171(12):1287-1296. [pmid: 25073599].
127 Sparks DL, Hunsaker JC 3rd, Amouyel P, et al. Angiotensin I-converting enzyme I/D polymorphism and suicidal behaviors. Am J Med Genet B Neuropsychiatr Genet. 2009;150B(2):290-294. [pmid: 18521860].
128 Matthews S, Spadoni A, Knox K, Strigo I, Simmons A. Combat-exposed war veterans at risk for suicide show hyperactivation of prefrontal cortex and anterior cingulate during error processing. Psychosom Med. 2012;74(5):471-475. [pmid: 22511726].
129 Serafini G, Pompili M, Innamorati M, et al. Affective temperamental profiles are associated with white matter hyperintensity and suicidal risk in patients with mood disorders. J Affect Disord. 2011;129(1–3):47-55. [pmid: 20708276].
130 Bagge C, Conner K. Looking for Suicide Warning Signs. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/looking-suicide-warning-signs. Accessed September 30, 2015.
131 Najavits LM. Assessment of Risk for Suicide, Violence and Related High-Risk Behaviors in Veterans. VA Health Services Research & Development. 2015. http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702991. Accessed September 30, 2015.
132 VA Eastern Colorado Health Care System, Department of Defense. Gutierrez P. Blister Packaging Medication to Increase Treatment Adherence and Clinical Response. ClinicalTrials.gov. 2015. NCT01118208. https://ClinicalTrials.gov/show/NCT01118208. Accessed September 28, 2015.
133 Walters H, Kulkarni M, Forman J, Roeder K, Travis J, Valenstein M. Feasibility and acceptability of interventions to delay gun access in VA mental health settings. Gen Hosp Psychiatry. Nov–Dec. 2012;34(6):692-698. [pmid: 22959420].
134 Britton PC, Bryan CJ, Valenstein M. Motivational interviewing for means restriction counseling with patients at risk for suicide. Cogn Behav Pract. Oct. 2014.
135 Caine ED. Forging an agenda for suicide prevention in the United States. Am J Public Health. 2013;103(5):822-829. [pmid: 23488515].
136 University of Wisconsin-Madison Integrative Medicine. Personalized, Proactive and Patient-Driven Care: Whole Health and Suicide Prevention. Published under subcontract with Pacific Institute for Research and Evaluation for the Veterans Health Administration/Office of Patient Centered Care & Cultural Transformation, Mental Health Innovations Task Force, Education Contract #VA777-12-C-0002, Task #7.1. 2014.
137 Bates MJ, Bowles SV. Review of Well-Being in the Context of Suicide Prevention and Resilience. Defense Centers of Excellence for Psychological Health & Traumatic Brain Injury (DCoE). 2011. http://www.dtic.mil/cgi-bin/GetTRDoc?Location=U2&doc=GetTRDoc.pdf&AD=ADA582882.
138 Hegerl U, Wittenburg L, Arensman E, et al. Optimizing Suicide Prevention Programs and Their Implementation in Europe (OSPI Europe): An evidence-based multi-level approach. BMC Public Health. 2009;9(428).
139 Hegerl U, Wittenburg L. The European Alliance Against Depression: A multilevel approach to the prevention of suicidal behavior. Psychiatr Serv. 2009;60(5):596-599. [pmid: 19411345].
140 Matarazzo BB, Hoffberg AS, Clemans TA, Signoracci GM, Simpson GK, Brenner LA. Cross-cultural adaptation of the Window to Hope: a psychological intervention to reduce hopelessness among U.S. veterans with traumatic brain injury. Brain Inj. 2014;28(10):1238-1247. [pmid: 24946053].
141 Institute of Medicine. Preventing Psychological Disorders in Service Members and their Families: An Assessment of Programs. Washington DC. National Academies Press. 2014.
142 Institute of Medicine. Returning Home from Iraq and Afghanistan: Preliminary Assessment of Readjustment Needs of Veterans, Service Members, and their Families. Washington, DC. The National Academies Press. 2010.
143 National Action Alliance for Suicide Prevention: Suicide Attempt Survivors Task Force. The Way Forward: Pathways to hope, recovery, and wellness with insights from lived experience. 2014. http://actionallianceforsuicideprevention.org/sites/actionallianceforsuicideprevention.org/files/The-Way-Forward-Final-2014-07-01.pdf. Accessed October 15, 2015.
144 Conner KR, Simons K. State of Innovation in Suicide Intervention Research with Military Populations. Suicide Life Threat Behav. 2015;45(3):281-292. [pmid: 25348613].
145 Kleiman EM, Adams LM, Kashdan TB, Riskind JH. Gratitude and grit indirectly reduce risk of suicidal ideations by enhancing meaning in life: Evidence for a mediated moderation model. Journal of Research in Personality. Oct. 2013;47(5):539-546.
146 Kleiman EM, Beaver JK. A meaningful life is worth living: meaning in life as a suicide resiliency factor. Psychiatry Res. Dec. 30. 2013;210(3):934-939. [pmid: 23978733].
147 Tsai AC, Lucas M, Sania A, Kim D, Kawachi I. Social integration and suicide mortality among men: 24-year cohort study of U.S. health professionals. Ann Intern Med. Jul. 15. 2014;161(2):85-95. [pmid: 25023247].
148 Tsai AC, Lucas M, Kawachi I. Association Between Social Integration and Suicide Among Women in the United States. JAMA Psychiatry. 2015.
149 Heisel MJ, Flett GL. Psychological resilience to suicide ideation among older adults. Clinical Gerontologist: The Journal of Aging and Mental Health. 2008;31(4):51-70.
150 Jobes DA. Managing suicidal risk: A collaborative approach. New York, NY. Guilford Press. 2006.
151 Read K. Instructor’s Manual for Dialectical Behavior Therapy with Marsha Linehan, Ph.D. Mill Valley, CA. Psychotherapy.net. 2013.
152 Brown GK, Ten Have T, Henriques GR, Xie SX, Hollander JE, Beck AT. Cognitive therapy for the prevention of suicide attempts: a randomized controlled trial. JAMA. Aug. 3. 2005;294(5):563-570. [pmid: 16077050].
153 Forkmann T, Wichers M, Geschwind N, et al. Effects of mindfulness-based cognitive therapy on self-reported suicidal ideation: Results from a randomised controlled trial in patients with residual depressive symptoms. Compr Psychiatry. 2014;55(8):1883-1890. [pmid: 25218397].
154 Britton PC, Conner KR, Maisto SA. An open trial of motivational interviewing to address suicidal ideation with hospitalized veterans. J Clin Psychol. Sep. 2012;68(9):961-971. [pmid: 22753109].
155 University of Washington, Military Suicide Research Consortium, Department of Veterans Affairs, Department of Defense. Military Continuity Project. ClinicalTrials.gov. 2013. https://ClinicalTrials.gov/show/NCT01829620. Accessed September 28, 2015.
156 National Center for Telehealth and Technology, Department of Defense, U. S. Army Medical Research and Materiel Command. Caring Letters for Military Suicide Prevention. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT01473771. Accessed September 28, 2015.
157 Comtois KA. Military Continuity Project (MCP). Military Suicide Research Consortium. 2013. NCT01829620. https://msrc.fsu.edu/funded-research/txt_msg. Accessed September 28, 2015.
158 Luxton DD, Thomas EK, Chipps J, et al. Caring letters for suicide prevention: Implementation of a multi-site randomized clinical trial in the U.S. military and veteran affairs healthcare systems. Contemp Clin Trials. 2014;37(2):252-260. [pmid: 24473106].
159 US Department of Veterans Affairs. Veterans Crisis Line. Funded by US Department of Health and Human Services. http://www.veteranscrisisline.net/. Accessed October 15, 2015.
160 Berrouiguet S, Gravey M, Le Galudec M, Alavi Z, Walter M. Post-acute crisis text messaging outreach for suicide prevention: A pilot study. Psychiatry Res. 2014;217(3):154-157. [pmid: 24736112].
161 Berrouiguet S, Alavi Z, Vaiva G, et al. SIAM (Suicide intervention assisted by messages): The development of a post-acute crisis text messaging outreach for suicide prevention. BMC Psychiatry. 2014;14:294. [pmid: 25404215].
162 Bush NE, Dobscha SK, Crumpton R, et al. A Virtual Hope Box smartphone app as an accessory to therapy: proof-of-concept in a clinical sample of veterans. Suicide Life Threat Behav. Feb. 2015;45(1):1-9. [pmid: 24828126].
163 National Center for Telehealth and Technology, The Geneva Foundation, Portland V. A. Medical Center. Virtual Hope Box - Effectiveness of a Smartphone App for Coping With Suicidal Ideation. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT01982773. Accessed September 28, 2015.
164 Ghahramanlou-Holloway M, Brown GK, Currier GW, et al. Safety Planning for Military (SAFE MIL): rationale, design, and safety considerations of a randomized controlled trial to reduce suicide risk among psychiatric inpatients. Contemp Clin Trials. 2014;39(1):113-123. [pmid: 25020008].
165 Currier GW, Brown GK, Brenner LA, et al. Rationale and study protocol for a two-part intervention: Safety planning and structured follow-up among veterans at risk for suicide and discharged from the emergency department. Contemp Clin Trials. 2015;43:179-184. [pmid: 25987482].
166 Knox KL, Stanley B, Currier GW, Brenner L, Ghahramanlou-Holloway M, Brown G. An emergency department-based brief intervention for veterans at risk for suicide (SAFE VET). Am J Public Health. Mar. 2012;102(Suppl 1):S33-S37. [pmid: 22390597].
167 Stanley B, Brown GK, Currier GW, Lyons C, Chesin M, Knox KL. Brief Intervention and Follow-Up for Suicidal Patients With Repeat Emergency Department Visits Enhances Treatment Engagement. Am J Public Health. Aug. 2015;105(8):1570-1572. [pmid: 26066951].
168 Bryan CJ. Brief Intervention for Short-Term Suicide Risk Reduction in Military Populations. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/risk_reduction. Accessed September 28, 2015.
169 University of Utah, The University of Texas Health Science Center at San Antonio. Brief Interventions for Short-Term Suicide Risk Reduction in Military Populations. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT02042131. Accessed September 28, 2015.
170 Smith G. Denver PHI Peer Project. Funded by VA Office of Patient Centered Care & Cultural Transformation.
171 University of Michigan, National Institutes of Health. Pfeiffer P. Peer Mentorship to Reduce Suicide Risk Following Psychiatric Hospitalization (PREVAIL Study). ClinicalTrials.gov. 2015. NCT02365116. https://ClinicalTrials.gov/show/NCT02365116. Accessed September 28, 2015.
172 Bronx Veterans Medical Research Foundation. High Risk Suicidal Behavior in Veterans. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT02462694. Accessed September 28, 2015.
173 Goodman M. High Risk Suicidal Veterans - Predictors of Suicide Risk and Efficacy of Dialectal Behavior Therapy. VISN 3 Mental Illness Research, Education & Clinical Center. http://www.mirecc.va.gov/visn3/clinical.asp#Behavior. Accessed September 30, 2015.
174 Henry M. Jackson Foundation for the Advancement of Military Medicine, Department of Veterans Affairs, Duke University, et al. Post Admission Cognitive Therapy (PACT) for the Inpatient Treatment of Military Personnel With Suicidal Behaviors. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT01359761. Accessed September 28, 2015.
175 Henry M. Jackson Foundation for the Advancement of Military Medicine, National Alliance for Research on Schizophrenia and Depression. Inpatient Post Admission Cognitive Therapy (PACT) for the Prevention of Suicide Attempts. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT01340859. Accessed September 28, 2015.
176 Henry M. Jackson Foundation for the Advancement of Military Medicine, Congressionally Directed Medical Research Programs. Pilot Trial of Inpatient Cognitive Therapy for the Prevention of Suicide in Military Personnel. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT01356186. Accessed September 28, 2015.
177 Department of Veterans Affairs. Crisis Line Facilitation. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT02459587. Accessed September 28, 2015.
178 University of Michigan, U. S. Army Medical Research and Materiel Command, Department of Defense, Department of Veterans Affairs. Intervening to Reduce Suicide Risk in Veterans With Substance Use Disorders. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT02439762. Accessed September 28, 2015.
179 Department of Veterans Affairs, Columbia University Department of Psychology College of Physicians & Surgeons, Rutgers University Bloustein Center for Survey Research. Mindfulness-Based Cognitive Therapy for Suicide Prevention. ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT01872338. Accessed September 28, 2015.
180 The Catholic University of America, University of Washington, Department of Veterans Affairs. Operation Worth Living Project With Suicidal Soldiers at Ft Stewart (OWL). ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT01300169. Accessed September 25, 2015.
181 Matarazzo B. Improving the Inpatient-to-Outpatient Transition. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/improving-inpatient-outpatient-transition. Accessed September 28, 2015.
182 Department of Veterans Affairs, Butler Hospital. Veterans Coping Long-term With Active Suicide (CLASP-VA). ClinicalTrials.gov. 2015. https://ClinicalTrials.gov/show/NCT01894841. Accessed September 28, 2015.
183 VA Eastern Colorado Health Care System, Department of Veterans Affairs, Department of Defense, Columbia University, University of Pennsylvania, Uniformed Services University of the Health Sciences. A Brief Intervention to Reduce Suicide Risk in Military Service Members and Veterans- Study 1. ClinicalTrials.gov. 2014. https://ClinicalTrials.gov/show/NCT01334541. Accessed September 28, 2015.
184 Office of Research & Development. Request for VA Research Community to Provide Input: Suicide Prevention Common Data Elements. US Department of Veterans Affairs. http://www.research.va.gov/resources/suicide_prevention.cfm. Accessed October 21, 2015.