# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Theresa Gleason, PhD, (Acting) Deputy Chief Research and Development Officer at the VA, with input from a technical expert panel. It is intended to update 3 previous VA ESP systematic reviews related to suicide screening and prevention published in 2009 and 2012.^1–3^ The scope and key questions of this report were determined during a topic refinement process that included a preliminary review of published peer-reviewed literature, discussion with internal partners and investigators, and consultation with content experts and key stakeholders.

This systematic review focuses on the accuracy of suicide risk assessment methods and the efficacy/effectiveness of suicide prevention interventions. Studies of associations between risk and protective factors and suicide are not included because of an ongoing large epidemiological study specifically among Army soldiers, Army STARRS, which will likely provide the strongest and most applicable evidence on this topic.9 A protocol describing the review was posted to the PROSPERO International Prospective Register of Systematic Reviews website before the review was initiated (http://www.crd.york.ac.uk/PROSPERO; registration number CRD42015019089).21 This review follows established systematic review methodology.22

Investigators created an analytic framework outlining the key questions, patient populations, interventions, and outcomes (Figure 1).

Figure 1 Analytic Framework

This systematic review is an update of previous VA ESP reviews that addresses the following key questions:

### Key Question 1

A. What are the accuracy and adverse effects of methods to identify Veterans and military personnel at increased risk for suicide and other suicidal self-directed violence?
B. Does accuracy and adverse effects vary by settings, delivery modes, targeted populations, or other factors?

### Key Question 2

What are the efficacy/effectiveness and adverse effects of suicide prevention interventions in reducing rates of suicide and other suicidal self-directed violence in Veterans and military personnel? Interventions include healthcare services directed towards:

A. Populations (eg, hotlines, outreach programs).
B. Individuals (eg, case management, follow-up).

### Key Question 3

What are important areas of ongoing research and current evidence gaps in research on suicide prevention in Veterans and military personnel, and how could they be addressed by future research?

Outcomes related to the efficacy and effectiveness of suicide risk assessment and prevention interventions included in this review are reduced suicide and other suicidal self-directed violence. Suicidal self-directed violence is behavior against oneself that deliberately results in injury or the potential for injury with evidence of suicidal intent, as defined by the Centers for Disease Control23 and the VA.24 Suicide is a fatal outcome of suicidal self-directed violence. Other types of self-directed violence are outside the scope of this review, including non-suicidal self-directed violence and self-harm, or composite outcomes that include these behaviors.

Adverse effects of suicide risk assessment and prevention interventions include any outcomes related to these activities that are not beneficial to the patients experiencing them. Criteria for adverse effects are intentionally broad, but need to be clinically relevant. Adverse effects generally include health outcomes as well as other types of outcomes, including anxiety and distress, labeling, and stigma.

## SEARCH STRATEGY

In conjunction with the systematic review investigators, a research librarian searched electronic bibliographic databases for relevant research published between January 1, 2008 and September 11, 2015, including MEDLINE, PubMed, PsycINFO, SocINDEX, Cochrane Central Register of Controlled Trials, and the Cochrane Database of Systematic Reviews. These dates were selected in order to capture studies published since the search dates of the previous VA ESP systematic reviews on this topic.1–3 Search terms and strategies are described in Appendix A. A search of the grey literature was conducted on July 16, 2015. In addition, citations from reference lists of relevant primary studies, reviews, conferences proceedings, and from clinical and research experts were reviewed. All citations were imported into an electronic database (EndNote^®^ X6, Thomson Reuters).

## STUDY SELECTION

Titles and abstracts were reviewed for inclusion using pre-specified eligibility criteria (Appendix B). Full-text articles identified as potentially relevant to the key questions were retrieved for further review and were independently examined by 2 reviewers using the eligibility criteria. Disagreements were resolved through consensus using a third reviewer.

Consistent with the previous VA ESP reviews, eligible studies included populations of Veterans, military personnel, and demographically comparable non-Veteran/military adults aged 18 and older from the US, United Kingdom (UK), Canada, New Zealand, and Australia. These countries were chosen because of their similarities to the US in terms of healthcare services as well as their involvement in the Operation Enduring Freedom/Operation Iraqi Freedom (OEF/OIF) conflicts. Studies enrolling participants substantially different from the general VA/military population (eg, children and adolescents) or with serious co-morbidities (eg, advanced cancer) were outside the scope of this review. Also, only English-language articles were included. Systematic reviews were eligible if they were timely, and contained relevant studies that addressed the key questions and met inclusion criteria for this update.

For Key Question 1, included studies evaluated the diagnostic accuracy and adverse effects of methods to assess risk for suicide and other suicidal self-directed violence, including instruments, checklists, and other approaches appropriate for clinical settings. Outcomes included measures of the accuracy of the risk assessment method (Table 1). Sensitivity measures were emphasized in this review because the serious morbidity and potential mortality associated with suicidal self-directed violence makes identifying individuals at risk for suicide, and thus providing opportunities for prevention interventions, more important than identifying individuals who at not at risk. This approach prioritizes sensitivity over specificity. Studies considering the setting, mode of delivery, and timing of risk assessment were also included. Studies were excluded that primarily determined associations between individual risk factors and suicidal self-directed violence, evaluated psychometric characteristics of instruments, or provided only descriptions of methods without reporting measures of accuracy.

Table 1 Measures of Test Accuracy

Statistical Term | Description
Sensitivity | Probability of a positive test among patients with the condition.
Specificity | Probability of a negative test among patients without the condition.
Positive predictive value (PPV) | Probability of the condition among patients with a positive test.
Negative predictive value (NPV) | Probability of not having the condition among patients with a negative test.
Receiver-operator characteristic curve (ROC) | A graph of sensitivity/(1-specificity).
Area under the ROC curve (AUC) | Reflection of how good the test is at discriminating between patients with and without the condition. Also referred to as the c-statistic. The greater the area, the better the test (0.50 no better than chance; 0.51–0.69 poor; 0.70–0.79 fair; 0.80–0.89 good; 0.90–0.99 excellent; 1.0 perfect).

For Key Question 2, studies of the efficacy or effectiveness of interventions were included that were specifically designed to prevent suicide and other suicidal self-directed violence. Eligible study designs included randomized controlled trials (RCTs), observational studies with comparison groups, and systematic reviews with these study designs. Efficacy studies evaluate an intervention under controlled circumstances, while effectiveness studies generally reflect more real-world conditions. Interventions included healthcare services directed towards populations (eg, hotlines, outreach programs) or individuals (eg, case management, follow-up services) that are clinically relevant to medical practice in the US. Both primary and secondary prevention studies were included. Primary prevention interventions are intended for individuals who have not experienced previous suicidal self-directed violence, while secondary prevention interventions are for those who have had previous episodes. Studies of interventions that are intended to primarily treat co-existing conditions and studies of pharmacotherapy were outside the scope of this update.

Key Question 3 addresses evidence gaps identified from the synthesis of studies addressing Key Questions 1 and 2. Consequently, studies included for Key Question 3 were identified from the searches for Key Questions 1 and 2. In addition, ongoing studies were selected from websites and other sources identified by our search of grey literature based on their relevance to the key questions. Our list of ongoing studies is likely incomplete because not all ongoing studies are included in these accessible sources.

## DATA ABSTRACTION

Data from included studies for Key Questions 1 and 2 were abstracted into a customized, pre-piloted database by one reviewer and over-read for accuracy by a second reviewer. Abstracted information included study design, setting, population, methodology, and results. Additional information for Key Question 1 included measures of accuracy, including sensitivity, specificity, positive and negative predictive value, or similar outcomes. Additional information for Key Question 2 included details of the intervention and control groups, important co-interventions, implementation factors, suicidal self-directed violence outcomes (suicide attempt and suicide), and other relevant outcomes.

## QUALITY ASSESSMENT

Two reviewers independently assessed the risk of bias of included studies using pre-specified criteria for RCTs,25 observational studies,26,27 and diagnostic accuracy studies26,28 (Appendix C). Each study was given an overall summary assessment of low, high, or unclear risk of bias. Disagreements were resolved through consensus using a third reviewer.

## DATA SYNTHESIS

Since this review is an update of previous VA ESP reviews, conclusions are based on qualitative synthesis of the findings of recently published studies as well as relevant studies from the previous reviews. Measures, interventions, outcomes, and study participants were too heterogeneous to combine in statistical meta-analysis.

## RATING THE BODY OF EVIDENCE

The overall strength of evidence for studies of interventions reviewed for Key Question 2 was determined using a method developed for the Agency for Healthcare Research and Quality’s (AHRQ) Evidence-based Practice Centers (EPC).29 This method does not provide strength of evidence grades for the diagnostic accuracy studies reviewed for Key Question 1. The AHRQ EPC method considers study limitations, directness, consistency, precision, and reporting bias to classify the strength of evidence for individual outcomes independently for RCTs and observational studies. Supplemental domains include dose-response association, plausible confounding that would decrease the observed effect, and strength of association, as well as separate guidance for applicability. Ratings were based on the following criteria:

- High = Very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies, the findings are stable, and another study would not change the conclusions.
- Moderate = Moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies and the findings are likely to be stable, but some doubt remains.
- Low = Limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). Additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient = No evidence, unable to estimate an effect, or no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.