# INTRODUCTION

## PURPOSE

This systematic review updates evidence on the accuracy of methods to identify individuals at increased risk for suicide, and the efficacy/effectiveness and adverse effects of healthcare service interventions in reducing suicide and other suicidal self-directed violence. Important areas of ongoing research and current evidence gaps on suicide prevention are also addressed. This report includes studies relevant to healthcare services provided to Veterans and military personnel in the United States (US).

Previous systematic reviews by the US Department of Veterans Affairs (VA) Evidence-based Synthesis Program (ESP) focused on strategies for suicide prevention in Veterans,1 suicide risk factors and risk assessment tools,2 and suicide prevention interventions and referral/follow-up services.3 While many of the studies included in the previous reviews fall outside the scope of this update, relevant studies are included in order to consolidate the evidence.

## BACKGROUND

Suicide is a major health concern in the US. A recent estimate of the overall US crude suicide rate was 12.4 per 100,000 population; the rate for males was nearly four times that for females (19.8 and 5.3 per 100,000).4 Suicide rates also vary by age and other demographic characteristics.4 Several factors have been associated with increased risk for suicide in epidemiological studies. The most consistently associated risk factors include the presence of mental health disorders, particularly depression, posttraumatic stress disorder, and substance abuse.2

Veterans and military personnel represent 20% of all known suicides in the US.5 Rates of suicide increased during the wars in Afghanistan and Iraq,6 and Veterans of these wars who reported suicidal ideation identify challenges during and after deployment as major contributors to their distress.7 Between 2000 and 2010, the suicide rate among Veterans rose higher than the rate among civilians.8 Female Veterans are at especially high risk relative to other women.8 These trends have led to new initiatives within the VA and military to address suicide prevention.

One such initiative is the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS), a multi-component epidemiological and neurobiological study. Army STARRS is designed to increase knowledge about risk and resilience factors for suicidality and support evidence-based recommendations to reduce suicides specifically among Army soldiers.9 Determination of risk and resilience factors in this population could lead to the development of additional methods to identify individuals at increased risk for suicide who may benefit from prevention interventions.10,11

## CURRENT PRACTICES

During the year prior to suicide, an estimated 77% of individuals make contact with primary care and 32% with mental health care clinicians.12 These encounters provide opportunities for suicide risk assessment and treatment of physical and psychiatric conditions that are associated with suicide.13 However, screening for suicide risk in general medical practice is not part of standard care in the US. The US Preventive Services Task (USPSTF) recently concluded that there is currently not enough research to support routine screening for suicide risk14 based on a systematic review of studies of screening and prevention interventions.15,16 This recommendation was intended for patients in primary care settings that do not have existing mental health disorders, emotional distress, or previous suicide attempts, and it did not specifically address Veterans and military personnel. The USPSTF encouraged primary care clinicians to be alert to the possibility of suicide during periods of high suicide risk, such as after discharge from a psychiatric facility or following an episode of self-harm or suicide attempt.14 Other recommendations from the USPSTF support routine screening in primary care for conditions associated with increased suicide risk. These include screening for depression,17 alcohol use,18 and intimate partner violence.19

The Veterans Health Administration and the Department of Defense issued their Clinical Practice Guideline for the Assessment and Management of Suicide Risk in 2013.^20^ Goals of the guideline are to reduce practice variation and provide a structural framework to reduce suicide and other suicidal self-directed violence, provide evidence-based recommendations for healthcare providers, and support the development of practice-based evidence. This guideline is organized around 3 clinical algorithms, including Assessment and Management of Risk for Suicide in Primary Care; Evaluation and Management of Risk for Suicide by Behavioral Health Providers; and Management of Patients at High Acute Risk for Suicide. However, the guideline does not recommend a specific risk assessment method or prevention intervention because of the lack of adequate supporting evidence.

Efforts to prevent suicide in individuals at high risk generally include treatment of underlying conditions and psychotherapy.1,3 Psychotherapy most often includes cognitive behavioral therapy and related approaches, such as dialectical behavior therapy and problem-solving therapy. Additional efforts include restriction of access to lethal means, including firearms and toxic agents.1

In addition to individual-level approaches to suicide prevention, initiatives have been implemented at organizational, health system, and community levels. These include multifaceted interventions emphasizing education and awareness, suicide hotlines and outreach programs, treatment coordination programs, and others. However, despite the existence of many types of services, very few studies demonstrating their effectiveness have been published.1 As a result, their influence on suicide prevention remains unclear.