# EXCLUDED REFERENCES

## Exclusion Codes: Reasons for Exclusion^*^ * Some citations had multiple reasons for being ineligible; only one exclusion code is listed in the table.

1 = Non-English language

2 = Ineligible country (ie, any country other than the US, UK, Canada, New Zealand, Australia)

3 = Ineligible population or setting (eg, children or adolescents, patients with serious comorbidities such as cancer or schizophrenia, nursing home populations, institutionalized populations)

4 = Study does not involve diagnostic accuracy of suicide risk assessment (KQ 1) or a healthcare service intervention to prevent suicide (KQ2)

5 = Study does not have a comparison group

6 = Ineligible outcome

7 = Ineligible study design (eg, case reports, case series)

8 = Ineligible publication type (eg, letter, editorial, publication only available as an abstract, protocol without results, non-systematic review or regulatory agency analysis)

9 = Ineligible systematic review (due to scope, inclusion criteria, outcomes, or limitations in quality)

Citation | Key Question | Exclusion Code
Abidin Z, Davoren M, Naughton L, Gibbons O, Nulty A, Kennedy HG. Susceptibility (risk and protective) factors for in-patient violence and self-harm: prospective study of structured professional judgement instruments START and SAPROF, DUNDRUM-3 and DUNDRUM-4 in forensic mental health services. BMC Psychiatry. 2013;13(Issue):197. | KQ1 | 6
Acosta FJ, Vega D, Torralba L, et al. Hopelessness and suicidal risk in bipolar disorder. A study in clinically nonsyndromal patients. Compr Psychiatry. 2012;53(Issue):1103–1109. | KQ1 | 2
Agosti V, Chen Y, Levin FR. Does Attention Deficit Hyperactivity Disorder increase the risk of suicide attempts? J Affect Disord. 2011;133(Issue):595–599. | KQ1 | 4
Albright G, Goldman R, Shockley KM, McDevitt F, Akabas S. Using an Avatar-Based Simulation to Train Families to Motivate Veterans with Post-Deployment Stress to Seek Help at the VA. Games for Health Journal. 2011;1(Issue):21–28. | KQ2 | 6
Alonzo D, Stanley B. A novel intervention for treatment of suicidal individuals. Psychiatr Serv. 2013;64(Issue):494. | KQ2 | 6
Alonzo D, Thompson RG, Stohl M, Hasin D. The influence of parental divorce and alcohol abuse on adult offspring risk of lifetime suicide attempt in the United States. Am J Orthopsychiatry. 2014;84(Issue):316–320. | KQ1 | 4
Altamura AC, Mundo E, Cattaneo E, et al. The MCP-1 gene (SCYA2) and mood disorders: preliminary results of a case-control association study. Neuroimmunomodulation. 2010;17(Issue):126–131. | KQ1 | 2
Anestis M. Predicting Suicide Risk in a Military Population. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/predicting-suicide-risk-military-population. Accessed September 25, 2015. | KQ1 | 8^*^
Anestis MD, Khazem LR, Mohn RS, Green BA. Testing the main hypotheses of the interpersonal-psychological theory of suicidal behavior in a large diverse sample of United States military personnel. Compr Psychiatry. 2015;60(Issue):78–85. | KQ1 | 4
Anestis MD, Silva C, Lavender JM, et al. Predicting nonsuicidal self-injury episodes over a discrete period of time in a sample of women diagnosed with bulimia nervosa: an analysis of self-reported trait and ecological momentary assessment based affective lability and previous suicide attempts. Int J Eat Disord. 2012;45(Issue):808–811. | KQ1 | 6
Antypa N, Antonioli M, Serretti A. Clinical, psychological and environmental predictors of prospective suicide events in patients with Bipolar Disorder. J Psychiatr Res. 2013;47(Issue):1800–1808. | KQ1 | 4
Aomori University of Health and Welfare. A Community-based Depression Screening Intervention for Middle-aged Suicide. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02468466. Accessed September 25, 2015. | KQ2 | 2
Arana A, Wentworth CE, Ayuso-Mateos JL, Arellano FM. Suicide-related events in patients treated with antiepileptic drugs. N Engl J Med. 2010;363(Issue):542–551. | KQ2 | 4
Arbore P. A San Francisco-Based Center Reaches Out with Supportive Services for Mid-Life and Older Adults at Risk for Depression and Suicide. Generations. 2014;38(Issue):27–29. | KQ1 | 8
Arnevik E, Wilberg T, Urnes O, Johansen M, Monsen JT, Karterud S. Psychotherapy for personality disorders: short-term day hospital psychotherapy versus outpatient individual therapy - a randomized controlled study. Eur Psychiatry. 2009;24(Issue):71–78. | KQ2 | 2
Aschan L, Goodwin L, Cross S, Moran P, Hotopf M, Hatch SL. Suicidal behaviours in South East London: prevalence, risk factors and the role of socio-economic status. J Affect Disord. 2013;150(Issue):441–449. | KQ1 | 4
Assistance Publique - Hôpitaux de Paris. Randomized Controlled and Prospective Trial of a Cohort of People Who Made a Suicide Attempt. ClinicalTrials.gov. 2012; https://ClinicalTrials.gov/show/NCT01176929. Accessed September 25, 2015. | KQ2 | 2
Ayer DW, Jayathilake K, Meltzer HY. The InterSePT suicide scale for prediction of imminent suicidal behaviors. Psychiatry Res. 2008;161(Issue):87–96. | KQ1 | 3
Baca-Garcia E, Perez-Rodriguez MM, Oquendo MA, et al. Estimating risk for suicide attempt: are we asking the right questions? Passive suicidal ideation as a marker for suicidal behavior. J Affect Disord. 2011;134(Issue):327–332. | KQ1 | 4
Bachynski KE, Canham-Chervak M, Black SA, Dada EO, Millikan AM, Jones BH. Mental health risk factors for suicides in the US Army, 2007--8. Inj Prev. 2012;18(Issue):405–412. | KQ1 | 4
Bagge C, Conner K. Looking for Suicide Warning Signs. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/looking-suicide-warning-signs. Accessed September 25, 2015. | KQ1 | 8^*^
Bagge CL, Lamis DA, Nadorff M, Osman A. Relations between hopelessness, depressive symptoms and suicidality: Mediation by reasons for living. J Clin Psychol. 2014;70(Issue):18–31. | KQ1 | 4
Bagge CL, Littlefield AK, Rosellini AJ, Coffey SF. Relations among behavioral and questionnaire measures of impulsivity in a sample of suicide attempters. Suicide Life Threat Behav. 2013;43(Issue):460–467. | KQ1 | 4
Bakst S, Rabinowitz J, Bromet EJ. Is poor premorbid functioning a risk factor for suicide attempts in first-admission psychosis? Schizophr Res. 2010;116(Issue):210–216. | KQ1 | 3
Baldessarini R, Tondo L. Suicidal risks during treatment of bipolar disorder patients with lithium versus anticonvulsants. Pharmacopsychiatry. 2009;42(Issue):72–75. | KQ1 | 4
Baldessarini RJ, Tondo L. Lithium and suicidal risk. Bipolar Disorders. 2008;10(Issue):114–115. | KQ1 | 4
Barber CR, Weinberg EF. Integrative Multidisciplinary Treatment in the public sector: A pilot study. Bull Menninger Clin. 2010;74(Issue):263–282. | KQ2 | 6
Barbui C, Esposito E, Cipriani A. Selective serotonin reuptake inhibitors and risk of suicide: A systematic review of observational studies. Can Med Assoc J. 2009;180(Issue):291–297. | KQ2 | 4
Bateman A, Fonagy P. 8-year follow-up of patients treated for borderline personality disorder: Mentalization-based treatment versus treatment as usual. Am J Psychiatry. 2008;165(Issue):631–638. | KQ2 | 4
Bateman A, Fonagy P. Randomized controlled trial of outpatient mentalization-based treatment versus structured clinical management for borderline personality disorder. Am J Psychiatry. 2009;166(Issue):1355–1364. | KQ2 | 4
Batey H, May J, Andrade J. Negative intrusive thoughts and dissociation as risk factors for self-harm. Suicide Life Threat Behav. 2010;40(Issue):35–49. | KQ1 | 6
Baud P, Perroud N, Courtet P, et al. Modulation of anger control in suicide attempters by TPH-1. Genes Brain Behav. 2009;8(Issue):97–100. | KQ1 | 2
Beautrais AL, Gibb SJ, Faulkner A, Fergusson DM, Mulder RT. Postcard intervention for repeat self-harm: randomised controlled trial. Br J Psychiatry. 2010;197(Issue):55–60. | KQ2 | 6
Beautrais AL, Gibb SJ, Fergusson DM, Horwood LJ, Larkin GL. Removing bridge barriers stimulates suicides: an unfortunate natural experiment. Aust N Z J Psychiatry. 2009;43(Issue):495–497. | KQ2 | 4
Bebbington PE, Minot S, Cooper C, et al. Suicidal ideation, self-harm and attempted suicide: results from the British psychiatric morbidity survey 2000. Eur Psychiatry. 2010;25(Issue):427–431. | KQ1 | 4
Becker M, Brown L, Ochshorn E, Diamond R. Risk for suicide among medicaid beneficiaries. Suicide Life Threat Behav. 2009;39(Issue):172–181. | KQ1 | 4
Bedi S, Nelson EC, Lynskey MT, et al. Risk for suicidal thoughts and behavior after childhood sexual abuse in women and men. Suicide Life Threat Behav. 2011;41(Issue):406–415. | KQ1 | 4
Beghi M, Rosenbaum JF. Risk factors for fatal and nonfatal repetition of suicide attempt: a critical appraisal. Curr Opin Psychiatry. 2010;23(Issue):349–355. | KQ1 | 4
Belnap BH, Schulberg HC, He F, Mazumdar S, Reynolds CF, III, Rollman BL. Electronic protocol for suicide risk management in research participants. J Psychosom Res. 2015;78(Issue):340–345. | KQ1 | 6
Ben-Efraim YJ, Wasserman D, Wasserman J, Sokolowski M. Family-based study of HTR2A in suicide attempts: observed gene, gene x environment and parent-of-origin associations. Mol Psychiatry. 2013;18(Issue):758–766. | KQ1 | 2
Ben-Efraim YJ, Wasserman D, Wasserman J, Sokolowski M. Family-based study of AVPR1B association and interaction with stressful life events on depression and anxiety in suicide attempts. Neuropsychopharmacology. 2013;38(Issue):1504–1511. | KQ1 | 2
Bergen H, Hawton K, Waters K, Cooper J, Kapur N. Psychosocial assessment and repetition of self-harm: the significance of single and multiple repeat episode analyses. J Affect Disord. 2010;127(Issue):257–265. | KQ1 | 6
Bergmans Y, Links PS. Reducing potential risk factors for suicide-related behavior with a group intervention for clients with recurrent suicide-related behavior. Ann Clin Psychiatry. 2009;21(Issue):17–25. | KQ2 | 6
Berlim MT, van den Eynde F, Tovar-Perdomo S, Chachamovich E, Zangen A, Turecki G. Augmenting antidepressants with deep transcranial magnetic stimulation (DTMS) in treatment-resistant major depression. World J Biol Psychiatry. 2014;15(Issue):570–578. | KQ2 | 6
Bernal G. UPR RP Suicide Prevention Program. https://projectreporter.nih.gov/project_info_description.cfm?aid=8286671. Accessed September 25, 2015. | KQ2 | 8
Bernert RA, Kim JS, Iwata NG, Perlis ML. Sleep disturbances as an evidence-based suicide risk factor. Current Psychiatry Reports. 2015;17(Issue):554. | KQ1 | 4
Berrouiguet S, Alavi Z, Vaiva G, et al. SIAM (Suicide intervention assisted by messages): The development of a post-acute crisis text messaging outreach for suicide prevention. BMC Psychiatry. 2014;14(Issue):294. | KQ2 | 8
Berrouiguet S, Gravey M, Le Galudec M, Alavi Z, Walter M. Post-acute crisis text messaging outreach for suicide prevention: A pilot study. Psychiatry Res. 2014;217(Issue):154–157. | KQ2 | 2
Betz ME, Miller M, Barber C, et al. Lethal means restriction for suicide prevention: beliefs and behaviors of emergency department providers. Depress Anxiety. 2013;30(Issue):1013–1020. | KQ2 | 6
Bhaskaran J, Wang Y, Roos L, Sareen J, Skakum K, Bolton JM. Method of suicide attempt and reaction to survival as predictors of repeat suicide attempts: a longitudinal analysis. J Clin Psychiatry. 2014;75(Issue):e802–808. | KQ1 | 4
Bhui KS, McKenzie K. Rates and risk factors by ethnic group for suicides within a year of contact with mental health services in England and Wales. Psychiatr Serv. 2008;59(Issue):414–420. | KQ1 | 4
Bilen K, Pettersson H, Owe-Larsson B, et al. Can early follow-up after deliberate self-harm reduce repetition? A prospective study of 325 patients. J Affect Disord. 2014;152–154(Issue):320–325. | KQ2 | 2
Bilen K, Ponzer S, Ottosson C, et al. Can repetition of deliberate self-harm be predicted? A prospective multicenter study validating clinical decision rules. J Affect Disord. 2013;149(Issue):253–258. | KQ1 | 2
Blasco-Fontecilla H, Delgado-Gomez D, Legido-Gil T, de Leon J, Perez-Rodriguez MM, Baca-Garcia E. Can the Holmes-Rahe Social Readjustment Rating Scale (SRRS) be used as a suicide risk scale? An exploratory study. Arch Suicide Res. 2012;16(Issue):13–28. | KQ1 | 2
Blasco-Fontecilla H, Delgado-Gomez D, Ruiz-Hernandez D, Aguado D, Baca-Garcia E, Lopez-Castroman J. Combining scales to assess suicide risk. J Psychiatr Res. 2012;46(Issue):1272–1277. | KQ1 | 2
Blasczyk-Schiep S, Kazen M, Kuhl J, Grygielski M. Appraisal of suicidal risk among adolescents and young adults through the Rorschach test. J Pers Assess. 2011;93(Issue):518–526. | KQ1 | 2
Blosnich JR, Brown GR, Shipherd JC, Kauth M, Piegari RI, Bossarte RM. Prevalence of gender identity disorder and suicide risk among transgender veterans utilizing Veterans Health Administration care. Am J Public Health. 2013;103(Issue):e27–e32. | KQ1 | 4
Blum N, St John D, Pfohl B, et al. Systems Training for Emotional Predictability and Problem Solving (STEPPS) for outpatients with borderline personality disorder: a randomized controlled trial and 1-year follow-up. Am J Psychiatry. 2008;165(Issue):468–478. | KQ2 | 6
Bohnert KM, Ilgen MA, McCarthy JF, Ignacio RV, Blow FC, Katz IR. Tobacco use disorder and the risk of suicide mortality. Addiction. 2014;109(Issue):155–162. | KQ1 | 4
Bolton JM, Cox BJ, Afifi TO, Enns MW, Bienvenu OJ, Sareen J. Anxiety disorders and risk for suicide attempts: findings from the Baltimore Epidemiologic Catchment area follow-up study. Depress Anxiety. 2008;25(Issue):477–481. | KQ1 | 4
Bolton JM, Pagura J, Enns MW, Grant B, Sareen J. A population-based longitudinal study of risk factors for suicide attempts in major depressive disorder. J Psychiatr Res. 2010;44(Issue):817–826. | KQ1 | 4
Bongiovi-Garcia ME, Merville J, Almeida MG, et al. Comparison of clinical and research assessments of diagnosis, suicide attempt history and suicidal ideation in major depression. J Affect Disord. 2009;115(Issue):183–188. | KQ1 | 6
Booth R, Keogh K, Doyle J, Owens T. Living through distress: A skills training group for reducing deliberate self-harm. Behav Cogn Psychother. 2014;42(Issue):156–165. | KQ2 | 6
Borges G, Angst J, Nock MK, Ruscio AM, Kessler RC. Risk factors for the incidence and persistence of suicide-related outcomes: a 10-year follow-up study using the National Comorbidity Surveys. J Affect Disord. 2008;105(Issue):25–33. | KQ1 | 4
Boyce N. Pilots of the future: Suicide prevention and the internet. The Lancet. 2010;376(Issue):1889–1890. | KQ2 | 8
Bradvik L, Mattisson C, Bogren M, Nettelbladt P. Long-term suicide risk of depression in the Lundby cohort 1947–1997--severity and gender. Acta Psychiatr Scand. 2008;117(Issue):185–191. | KQ1 | 2
Braithwaite E, Charette Y, Crocker AG, Reyes A. The predictive validity of clinical ratings of the Short-Term Assessment of Risk and Treatability (START). Int J Forensic Ment Health. 2010;9(Issue):271–281. | KQ1 | 4
Brechlin T, Myers K. 0077 Good from tragedy? enhancing prevention, intervention and postvention of suicide through the comprehensive, multidisciplinary reviews of suicide deaths in utah. Inj Prev. 2015;21(Issue):A19. | KQ2 | 8
Brenner L, Military Suicide Research Consortium, VA Eastern Colorado Health Care System. Window to Hope-Evaluating a Psychological Treatment for Hopelessness Among Veterans With Traumatic Brain Injury (WtoH). ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01691378. Accessed September 25, 2015. | KQ2 | 8
Brenner L, Simpson G, Forster J, et al. Window to hope: Preliminary results from a randomized controlled trial (RCT) of a psychological treatment for hopelessness among US veterans with traumatic brain injury (TBI). Brain Inj. 2014;28(Issue):737. | KQ2 | 6
Britton PC, Bossarte RM, Thompson C, Kemp J, Conner KR. Influences on call outcomes among veteran callers to the National Veterans Crisis Line. Suicide Life Threat Behav. 2013;43(Issue):494–502. | KQ2 | 6
Britton PC, Ilgen MA, Rudd MD, Conner KR. Warning signs for suicide within a week of healthcare contact in Veteran decedents. Psychiatry Res. 2012;200(Issue):395–399. | KQ1 | 4
Britton PC, Ilgen MA, Valenstein M, Knox K, Claassen CA, Conner KR. Differences between veteran suicides with and without psychiatric symptoms. Am J Public Health. 2012;102 Suppl 1(Issue):S125–130. | KQ1 | 4
Bronx Veterans Medical Research Foundation. High Risk Suicidal Behavior in Veterans. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02462694. Accessed September 25, 2015. | KQ2 | 8^†^
Brooke Army Medical Center. Ketamine for Acute Suicidal Ideation in the Emergency Department: Randomized Controlled Trial. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01892995. Accessed September 25, 2015. | KQ2 | 8
Brown GK, Green KL. A review of evidence-based follow-up care for suicide prevention: where do we go from here? Am J Prev Med. 2014;47(Issue):S209–215. | KQ2 | 8
Brown MZ, Linehan MM, Comtois KA, Murray A, Chapman AL. Shame as a prospective predictor of self-inflicted injury in borderline personality disorder: a multi-modal analysis. Behav Res Ther. 2009;47(Issue):815–822. | KQ1 | 4
Brown S, Langrish M. Evaluation of a risk assessment tool to predict violent behaviour by patients detained in a psychiatric intensive care unit. Journal of Psychiatric Intensive Care. 2012;8(Issue):35–41. | KQ1 | 6
Brundin L, Bjorkqvist M, Traskman-Bendz L, Petersen A. Increased orexin levels in the cerebrospinal fluid the first year after a suicide attempt. J Affect Disord. 2009;113(Issue):179–182. | KQ1 | 2
Bryan CJ, Bryan AO, Ray-Sannerud BN, Etienne N, Morrow CE. Suicide attempts before joining the military increase risk for suicide attempts and severity of suicidal ideation among military personnel and veterans. Compr Psychiatry. 2014;55(Issue):534–541. | KQ1 | 4
Bryan CJ, Clemans TA. Repetitive traumatic brain injury, psychological symptoms, and suicide risk in a clinical sample of deployed military personnel. JAMA Psychiatry. 2013;70(Issue):686–691. | KQ1 | 4
Bryan CJ, Cukrowicz KC. Associations between types of combat violence and the acquired capability for suicide. Suicide Life Threat Behav. 2011;41(Issue):126–136. | KQ1 | 6
Bryan CJ, David Rudd M, Wertenberger E, et al. Improving the detection and prediction of suicidal behavior among military personnel by measuring suicidal beliefs: an evaluation of the Suicide Cognitions Scale. J Affect Disord. 2014;159(Issue):15–22. | KQ1 | 4
Bryan CJ, Dhillon-Davis LE, Dhillon-Davis KK. Emotional impact of a video-based suicide prevention program on suicidal viewers and suicide survivors. Suicide Life Threat Behav. 2009;39(Issue):623–632. | KQ2 | 6
Bryan CJ, Gonzales J, Rudd DM, et al. Depression Mediates the Relation of Insomnia Severity with Suicide Risk in Three Clinical Samples of U.S. Military Personnel. Depress Anxiety. 2015(Issue). | KQ1 | 4
Bryan CJ, Griffith JH, Pace BT, et al. Combat exposure and risk for suicidal thoughts and behaviors among military personnel and veterans: A systematic review and meta-analysis. Suicide Life Threat Behav. 2015;45(Issue):633–649. | KQ1 | 4
Bryan CJ, Hernandez AM, Allison S, Clemans T. Combat exposure and suicide risk in two samples of military personnel. J Clin Psychol. 2013;69(Issue):64–77. | KQ1 | 6
Bryan CJ, Jennings KW, Jobes DA, Bradley JC. Understanding and preventing military suicide. Arch Suicide Res. 2012;16(Issue):95–110. | KQ1 & KQ2 | 8
Bryan CJ, McNaugton-Cassill M, Osman A, Hernandez AM. The associations of physical and sexual assault with suicide risk in nonclinical military and undergraduate samples. Suicide Life Threat Behav. 2013;43(Issue):223–234. | KQ1 | 4
Bryan CJ, Steiner-Pappalardo N, Rudd MD. Exposure to a mnemonic interferes with recall of suicide warning signs in a community-based suicide prevention program. Suicide Life Threat Behav. 2009;39(Issue):194–203. | KQ2 | 6
Bryan CJ. Brief Intervention for Short-Term Suicide Risk Reduction in Military Populations. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/risk_reduction. Accessed September 25, 2015. | KQ2 | 8^†^
Bryan CJ. The clinical utility of a brief measure of perceived burdensomeness and thwarted belongingness for the detection of suicidal military personnel. J Clin Psychol. 2011;67(Issue):981–992. | KQ1 | 6
Bulik CM, Thornton L, Pinheiro AP, et al. Suicide attempts in anorexia nervosa. Psychosom Med. 2008;70(Issue):378–383. | KQ1 | 4
Butler Hospital. Evaluation of the Coping Long Term With Active Suicide Program (CLASP). ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02313753. Accessed September 25, 2015. | KQ2 | 8
Caine ED. Forging an agenda for suicide prevention in the United States. Am J Public Health. 2013;103(Issue):822–829. | KQ2 | 8
Capron DW, Blumenthal H, Medley AN, et al. Anxiety sensitivity cognitive concerns predict suicidality among smokers. J Affect Disord. 2012;138(Issue):239–246. | KQ1 | 6
Carlberg L, Schosser A, Calati R, et al. Association study of CREB1 polymorphisms and suicidality in MDD: Results from a European multicenter study on treatment resistant depression. Int J Neurosci. 2015;125(Issue):336–343. | KQ1 | 4
Carlson EB, McDade-Montez E, Armstrong J, Dalenberg C, Loewenstein RJ. Development and initial validation of the Structured Interview for Self-Destructive Behaviors. J Trauma Dissociation. 2013;14(Issue):312–327. | KQ1 | 6
Carlsten A, Waern M. Are sedatives and hypnotics associated with increased suicide risk of suicide in the elderly? BMC Geriatr. 2009;9(Issue):20. | KQ1 | 2
Carolina MUoS. Chronotherapy Randomized Controlled Trial. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02176824. Accessed September 25, 2015. | KQ2 | 8
Carr ER, Woods AM, Vahabzadeh A, Sutton C, Wittenauer J, Kaslow NJ. PTSD, depressive symptoms, and suicidal ideation in African American women: a mediated model. J Clin Psychol Med Settings. 2013;20(Issue):37–45. | KQ1 | 4
Castle K, Conner K, Kaukeinen K, Tu X. Perceived racism, discrimination, and acculturation in suicidal ideation and suicide attempts among black young adults. Suicide Life Threat Behav. 2011;41(Issue):342–351. | KQ1 | 4
Catanese AA, John MS, Di Battista J, Clarke DM. Acute cognitive therapy in reducing suicide risk following a presentation to an emergency department. Behaviour Change. 2009;26(Issue):16–26. | KQ2 | 6
Catanzarite JA, Robinson MD. Peer Education in Campus Suicide Prevention. New Directions for Student Services. 2013;2013(Issue):43–53. | KQ2 | 8
Center for Substance Abuse Treatment. Substance Abuse and Suicide Prevention: Evidence and Implications—A White Paper. Rockville, MD: Substance Abuse and Mental Health Services Administration (DHHS Pub. No. SMA-08-4352);2008. | KQ2 | 8
Centre for Addiction and Mental Health, Canadian Institutes of Health Research, Simon Fraser University. DBT for Chronically Self-harming Individuals With BPD: Evaluating the Clinical &Cost Effectiveness of a 6 mo. Treatment (FASTER-DBT). ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02387736. Accessed September 25, 2015. | KQ2 | 8
Centre Hospitalier Universitaire de Nīmes. Effects of Ketamine in the Acute Phase of Suicidal Ideation. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02299440. Accessed September 25, 2015. | KQ2 | 2
Cerecor. A Randomized, Double-Blind, Placebo-Controlled, Sequential Parallel Study of CERC-301 in the Adjunctive Treatment of Subjects With Severe Depression and Recent Active Suicidal Ideation Despite Antidepressant Treatment. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01941043. Accessed September 25, 2015. | KQ2 | 8
Cha CB, Najmi S, Park JM, Finn CT, Nock MK. Attentional bias toward suicide-related stimuli predicts suicidal behavior. J Abnorm Psychol. 2010;119(Issue):616–622. | KQ1 | 4
Chamberlain P, Goldney R, Delfabbro P, Gill T, Dal Grande L. Suicidal ideation. The clinical utility of the K10. Crisis. 2009;30(Issue):39–42. | KQ1 | 6
Chan SW, Chien WT, Tso S. The qualitative evaluation of a suicide prevention and management programme by general nurses. J Clin Nurs. 2008;17(Issue):2884–2894. | KQ2 | 4
Chandrasekaran R, Gnanaselane J. Predictors of repeat suicidal attempts after first-ever attempt: A two-year follow-up study. Hong Kong Journal of Psychiatry. 2008;18(Issue):131–135. | KQ1 | 2
Chang EC, Sanna LJ, Hirsch JK, Jeglic EL. Loneliness and negative life events as predictors of hopelessness and suicidal behaviors in Hispanics: evidence for a diathesis-stress model. J Clin Psychol. 2010;66(Issue):1242–1253. | KQ1 | 4
Chang EC, Yu EA, Lee JY, Hirsch JK, Kupfermann Y, Kahle ER. An examination of optimism/pessimism and suicide risk in primary care patients: Does belief in a changeable future make a difference? Cognit Ther Res. 2013;37(Issue):796–804. | KQ1 | 4
Chapman AL, Derbidge CM, Cooney E, Hong PY, Linehan MM. Temperament as a prospective predictor of self-injury among patients with borderline personality disorder. J Pers Disord. 2009;23(Issue):122–140. | KQ1 | 4
Cheatle MD. Assessing suicide risk in patients with chronic pain and depression. J Fam Pract. 2014;63(Issue):S6–S11. | KQ1 | 7
Chesin M, Stanley B. Risk assessment and psychosocial interventions for suicidal patients. Bipolar Disord. 2013;15(Issue):584–593. | KQ1 & KQ2 | 8
Children’s Hospital Medical Center in Cincinnati. Suicidal Thought and Biological Markers (STM). ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01992445. Accessed September 25, 2015. | KQ1 | 3
Christensen H, Calear AL, Van Spijker B, et al. Psychosocial interventions for suicidal ideation, plans, and attempts: A database of randomised controlled trials. BMC Psychiatry. 2014;14(Issue):86. | KQ2 | 8
Chu J, Floyd R, Diep H, Pardo S, Goldblum P, Bongar B. A tool for the culturally competent assessment of suicide: the Cultural Assessment of Risk for Suicide (CARS) measure. Psychol Assess. 2013;25(Issue):424–434. | KQ1 | 6
Cimini MD, Rivero EM. Postsuicide Intervention as a Prevention Tool: Developing a Comprehensive Campus Response to Suicide and Related Risk. New Directions for Student Services. 2013;2013(Issue):83–96. | KQ2 | 6
Cipriani A, Hawton K, Stockton S, Geddes JR. Lithium in the prevention of suicide in mood disorders: updated systematic review and meta-analysis. BMJ. 2013;346(Issue):f3646. | KQ2 | 9
Clarkin JF, Levy KN, Lenzenweger MF, Kernberg OF. Evaluating three treatments for borderline personality disorder: a multiwave study. Am J Psychiatry. 2007;164(Issue):922–928. | KQ1 | 6
Clayton P, Auster T. Strategies for the Prevention and Treatment of Suicidal Behavior. Focus. 2008;6(Issue):15–21. | KQ2 | 8
Comtois KA. Military Continuity Project (MCP). Military Suicide Research Consortium. 2013; NCT01829620. https://msrc.fsu.edu/funded-research/txt_msg. Accessed September 25, 2015. | KQ2 | 8^†^
Congdon P. Latent variable model for suicide risk in relation to social capital and socio-economic status. Soc Psychiatry Psychiatr Epidemiol. 2012;47(Issue):1205–1219. | KQ1 | 4
Conner KR, Bagge CL, Goldston DB, Ilgen MA. Alcohol and suicidal behavior: what is known and what can be done. Am J Prev Med. 2014;47(Issue):S204–208. | KQ2 | 8
Conner KR, McCarthy MD, Bajorska A, Caine ED, Tu XM, Knox KL. Mood, anxiety, and substance-use disorders and suicide risk in a military population cohort. Suicide Life Threat Behav. 2012;42(Issue):699–708. | KQ1 | 4
Conner KR, Simons K. State of Innovation in Suicide Intervention Research with Military Populations. Suicide Life Threat Behav. 2015;45(Issue):281–292. | KQ2 | 8
Conner KR, Wood J, Pisani AR, Kemp J. Evaluation of a suicide prevention training curriculum for substance abuse treatment providers based on Treatment Improvement Protocol Number 50. J Subst Abuse Treat. 2013;44(Issue):13–16. | KQ2 | 6
Conrad AK, Jacoby AM, Jobes DA, et al. A psychometric investigation of the Suicide Status Form II with a psychiatric inpatient sample. Suicide Life Threat Behav. 2009;39(Issue):307–320. | KQ1 | 4
Cook TB, Davis MS. Assessing legal strains and risk of suicide using archived court data. Suicide Life Threat Behav. 2012;42(Issue):495–506. | KQ1 | 4
Coope C, Gunnell D, Hollingworth W, et al. Suicide and the 2008 economic recession: Who is most at risk? Trends in suicide rates in England and Wales 2001–2011. Soc Sci Med. 2014;117(Issue):76–85. | KQ1 | 4
Cooper J, Kapur N, Dunning J, Guthrie E, Appleby L, Mackway-Jones K. A clinical tool for assessing risk after self-harm. Ann Emerg Med. 2006;48(Issue):459–466. | KQ1 | 6
Cooper J, Kapur N, Mackway-Jones K. A comparison between clinicians’ assessment and the Manchester Self-Harm Rule: a cohort study. Emerg Med J. 2007;24(Issue):720–721. | KQ1 | 6
Cooper J, Kapur N, Webb R, et al. Suicide after deliberate self-harm: a 4-year cohort study. Am J Psychiatry. 2005;162(Issue):297–303. | KQ1 | 4
Cornette MM, Schlotthauer AE, Berlin JS, et al. The public health approach to reducing suicide: opportunities for curriculum development in psychiatry residency training programs. Acad Psychiatry. 2014;38(Issue):575–584. | KQ2 | 8
Cougle J. Using Anger-Reductions Treatment to Reduce Suicide Risk. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/using-anger-reduction-treatment-reduce-suicide-risk. Accessed September 25, 2015. | KQ2 | 8
Cougnard A, Verdoux H, Grolleau A, Moride Y, Begaud B, Tournier M. Impact of antidepressants on the risk of suicide in patients with depression in real-life conditions: a decision analysis model. Psychol Med. 2009;39(Issue):1307–1315. | KQ2 | 2
Cox DW, Ghahramanlou-Holloway M, Greene FN, et al. Suicide in the United States Air Force: Risk factors communicated before and at death. J Affect Disord. 2011;133(Issue):398–405. | KQ1 | 4
Crowder MK, Kemmelmeier M. Untreated depression predicts higher suicide rates in U.S. Honor cultures. J Cross Cult Psychol. 2014;45(Issue):1145–1161. | KQ1 | 4
Crowe M, Inder M, Moor S, Luty SE, Carter J. Suicide attempts in young people with bipolar disorder: Results from a psychotherapy intervention and three years follow-up. Bipolar Disorders. 2013;15(Issue):97. | KQ2 | 8
Cuijpers P, de Beurs DP, van Spijker BA, Berking M, Andersson G, Kerkhof AJ. The effects of psychotherapy for adult depression on suicidality and hopelessness: a systematic review and meta-analysis. J Affect Disord. 2013;144(Issue):183–190. | KQ2 | 6
Currier GW, Brown GK, Brenner LA, et al. Rationale and study protocol for a two-part intervention: Safety planning and structured follow-up among veterans at risk for suicide and discharged from the emergency department. Contemp Clin Trials. 2015;43(Issue):179–184. | KQ2 | 8^†^
Currier GW, Fisher SG, Caine ED. Mobile crisis team intervention to enhance linkage of discharged suicidal emergency department patients to outpatient psychiatric services: a randomized controlled trial. Acad Emerg Med. 2010;17(Issue):36–43. | KQ2 | 6
Cylus J, Glymour MM, Avendano M. Do generous unemployment benefit programs reduce suicide rates? A state fixed-effect analysis covering 1968–2008. Am J Epidemiol. 2014;180(Issue):45–52. | KQ1 | 7
Dalca IM, McGirr A, Renaud J, Turecki G. Gender-specific suicide risk factors: a case-control study of individuals with major depressive disorder. J Clin Psychiatry. 2013;74(Issue):1209–1216. | KQ1 | 4
Dale R, Power K, Kane S, Stewart AM, Murray L. The role of parental bonding and early maladaptive schemas in the risk of suicidal behavior repetition. Arch Suicide Res. 2010;14(Issue):311–328. | KQ1 | 4
Davidson CL, Babson KA, Bonn-Miller MO, Souter T, Vannoy S. The impact of exercise on suicide risk: examining pathways through depression, PTSD, and sleep in an inpatient sample of veterans. Suicide Life Threat Behav. 2013;43(Issue):279–289. | KQ1 | 4
Davidson KM, Tyrer P, Norrie J, Palmer SJ, Tyrer H. Cognitive therapy v. usual treatment for borderline personality disorder: Prospective 6-year follow-up. Br J Psychiatry. 2010;197(Issue):456–462. | KQ2 | 4
De Silva S, Parker A, Purcell R, Callahan P, Liu P, Hetrick S. Mapping the evidence of prevention and intervention studies for suicidal and self-harming behaviors in young people. Crisis. 2013;34(Issue):223–232. | KQ2 | 3
Dell’osso L, Mandelli L, Carlini M, et al. Temperamental and genetic predictors of suicide attempt and self-mutilation. Neuropsychobiology. 2013;68(Issue):250–257. | KQ1 | 2
Denckla CA, Bailey R, Jackson C, Tatarakis J, Chen CK. A novel adaptation of distress tolerance skills training among military veterans: Outcomes in suicide-related events. Cognitive and Behavioral Practice Apr. Apr 2014(Issue). | KQ2 | 6
Dennehy EB, Marangell LB, Martinez J, Balasubramani G, Wisniewski SR. Clinical and functional outcomes of patients who experience partial response to citalopram: Secondary analysis of STAR*D. J Psychiatr Pract. 2014;20(Issue):178–187. | KQ2 | 6
Department of Veterans A. Executive Dysfunction and Suicide in Psychiatric Outpatients and Inpatients. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01043432. Accessed September 25, 2015. | KQ2 | 8
Department of Veterans Affairs, Butler Hospital. Veterans Coping Long-term With Active Suicide (CLASP-VA). ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01894841. Accessed September 25, 2015. | KQ2 | 8^†^
Department of Veterans Affairs, Columbia University Department of Psychology College of Physicians & Surgeons, Rutgers University Bloustein Center for Survey Research. Mindfulness-Based Cognitive Therapy for Suicide Prevention. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01872338. Accessed September 25, 2015. | KQ2 | 8^†^
Department of Veterans Affairs. Adjunctive BBTI for SI. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02248675. Accessed September 25, 2015. | KQ2 | 6
Department of Veterans Affairs. Crisis Line Facilitation. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02459587. Accessed September 25, 2015. | KQ2 | 8^†^
Department of Veterans Affairs. Increasing Treatment Seeking Among Suicidal Veterans Calling the Crisis Line. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01771965. Accessed September 25, 2015. | KQ2 | 8
Department of Veterans Affairs. Motivational Interviewing to Prevent Suicide in High Risk Veterans. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01544127. Accessed September 25, 2015. | KQ2 | 8
Desseilles M, Perroud N, Guillaume S, et al. Is it valid to measure suicidal ideation by depression rating scales? J Affect Disord. 2012;136(Issue):398–404. | KQ1 | 2
Dewey L, Allwood M, Fava J, Arias E, Pinizzotto A, Schlesinger L. Suicide by cop: clinical risks and subtypes. Arch Suicide Res. 2013;17(Issue):448–461. | KQ1 | 4
Diamond GS, Wintersteen MB, Brown GK, et al. Attachment-based family therapy for adolescents with suicidal ideation: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2010;49(Issue):122–131. | KQ2 | 3
Ding Y, Lawrence N, Olie E, et al. Prefrontal cortex markers of suicidal vulnerability in mood disorders: A model-based structural neuroimaging study with a translational perspective. Translational psychiatry. 2015;5(Issue). | KQ1 | 4
Dour HJ, Cha CB, Nock MK. Evidence for an emotion-cognition interaction in the statistical prediction of suicide attempts. Behav Res Ther. 2011;49(Issue):294–298. | KQ1 | 3
Draper J, Murphy G, Vega E, Covington DW, McKeon R. Helping Callers to the National Suicide Prevention Lifeline Who Are at Imminent Risk of Suicide: The Importance of Active Engagement, Active Rescue, and Collaboration Between Crisis and Emergency Services. Suicide Life Threat Behav. 2015;45(Issue):261–270. | KQ2 | 4
Dube P, Kroenke K, Bair MJ, Theobald D, Williams LS. The P4 screener: Evaluation of a brief measure for assessing potential suicide risk in 2 randomized effectiveness trials of primary care and oncology patients [NCT00118430; NCT00313573]. Prim Care Companion J Clin Psychiatry. 2010;12(Issue). | KQ1 | 4
Ducasse D, Rene E, Beziat S, Guillaume S, Courtet P, Olie E. Acceptance and commitment therapy for management of suicidal patients: A pilot study. Psychother Psychosom. 2014;83(Issue):374–376. | KQ2 | 2
Dunning J. A calm approach to suicide prevention. Community Care. 2010(Issue):26–27. | KQ2 | 8
Dwivedi Y, Pandey GN. Elucidating biological risk factors in suicide: role of protein kinase A. Prog Neuropsychopharmacol Biol Psychiatry. 2011;35(Issue):831–841. | KQ1 | 4
Dwivedi Y. Brain-derived neurotrophic factor and suicide pathogenesis. Ann Med. 2010;42(Issue):87–96. | KQ1 | 4
Edelstein BA, Heisel MJ, McKee DR, et al. Development and Psychometric Evaluation of the Reasons for Living—Older Adults Scale: A Suicide Risk Assessment Inventory. Gerontologist. 2009;49(Issue):736–745. | KQ1 | 6
Edwards SJ, Sachmann MD. No-suicide contracts, no-suicide agreements, and no-suicide assurances: A study of their nature, utilization, perceived effectiveness, and potential to cause harm. Crisis. 2010;31(Issue):290–302. | KQ2 | 4
Emory University. Group Interventions for Suicidal African Americans. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02227160. Accessed September 25, 2015. | KQ2 | 8
Engel CC, Bray RM, Jaycox LH, et al. Implementing collaborative primary care for depression and posttraumatic stress disorder: Design and sample for a randomized trial in the U.S. military health system. Contemp Clin Trials. 2014;39(Issue):310–319. | KQ2 | 6
Far Eastern Memorial Hospital. Whole Person Care Research Program of the Suicide Cases Consultative Services. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT02158611. Accessed September 25, 2015. | KQ2 | 2
Fava M, Massachusetts General Hospital. Adaptation of Dialectical Behavior Therapy Skills-Groups for Individuals With Suicidal Ideation and Depression. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01441258. Accessed September 25, 2015. | KQ2 | 8
Fawcett JA, Baldessarini RJ, Coryell WH, Silverman MM, Stein DJ. Defining and managing suicidal risk in patients taking psychotropic medications. J Clin Psychiatry. 2009;70(Issue):782–789. | KQ1 & KQ2 | 8
Federici A, Wisniewski L. An intensive DBT program for patients with multidiagnostic eating disorder presentations: A case series analysis. Int J Eat Disord. 2013;46(Issue):322–331. | KQ2 | 7
Fedyszyn IE, Harris MG, Robinson J, Paxton SJ. Classification Algorithm for the Determination of Suicide Attempt and Suicide (CAD-SAS). Development and psychometric properties. Crisis. 2012;33(Issue):151–161. | KQ1 | 4
Fedyszyn IE, Robinson J, Harris MG, Paxton SJ, Francey S. Predictors of suicide-related behaviors during treatment following a first episode of psychosis: the contribution of baseline, past, and recent factors. Schizophr Res. 2012;140(Issue):17–24. | KQ1 | 3
Fedyszyn IE, Robinson J, Matyas T, Harris MG, Paxton SJ. Temporal pattern of suicide risk in young individuals with early psychosis. Psychiatry Res. 2010;175(Issue):98–103. | KQ1 | 4
Fiedorowicz JG, Leon AC, Keller MB, Solomon DA, Rice JP, Coryell WH. Do risk factors for suicidal behavior differ by affective disorder polarity? Psychol Med. 2009;39(Issue):763–771. | KQ1 | 4
Fine TH, Contractor AA, Tamburrino M, et al. Validation of the telephone-administered PHQ-9 against the in-person administered SCID-I major depression module. J Affect Disord. 2013;150(Issue):1001–1007. | KQ1 | 6
Fink M, Kellner CH, McCall WV. The role of ECT in suicide prevention. J ECT. 2014;30(Issue):5–9. | KQ2 | 8
Finney EJ, Buser SJ, Schwartz J, Archibald L, Swanson R. Suicide prevention in fire service: The Houston Fire Department (HFD) model. Aggr Violent Behav. 2015;21(Issue):1–4. | KQ2 | 7
Fishbain DA, Lewis JE, Bruns D, Gao J, Disorbio JM, Meyer L. Patient predictor variables for six forms of suicidality. Eur J Pain. 2012;16(Issue):706–717. | KQ1 | 6
Fitzpatrick JJ. Preventing suicide: Developing meaning in life. Arch Psychiatr Nurs. 2009;23(Issue):275–276. | KQ2 | 8
Fleischmann A, Bertolote JM, Wasserman D, et al. Effectiveness of brief intervention and contact for suicide attempters: a randomized controlled trial in five countries. Bull World Health Organ. 2008;86(Issue):703–709. | KQ2 | 2
Florentine JB, Crane C. Suicide prevention by limiting access to methods: A review of theory and practice. Soc Sci Med. 2010;70(Issue):1626–1632. | KQ2 | 8
Florida State University, Department of Defense. Cognitive Anxiety Sensitivity Treatment for Suicide. ClinicalTrials.gov. 2013; https://ClinicalTrials.gov/show/NCT01947179. Accessed September 25, 2015. | KQ2 | 8
Florida State University, Department of Defense. Depression and Anxiety Reduction Treatment for Suicide (DARTS). ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01941862. Accessed September 25, 2015. | KQ2 | 8
Florida State University. Controlled Evaluation of a Computerized Anger-reduction Treatment for Suicide Prevention. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01918696. Accessed September 25, 2015. | KQ2 | 6
Forkmann T, Wichers M, Geschwind N, et al. Effects of mindfulness-based cognitive therapy on self-reported suicidal ideation: Results from a randomised controlled trial in patients with residual depressive symptoms. Compr Psychiatry. 2014;55(Issue):1883–1890. | KQ2 | 2
Fountoulakis KN, Gonda X, Rihmer Z. Suicide prevention programs through community intervention. J Affect Disord.130(Issue):10–16. | KQ2 | 8
Fountoulakis KN, Pantoula E, Siamouli M, et al. Development of the Risk Assessment Suicidality Scale (RASS): a population-based study. J Affect Disord. 2012;138(Issue):449–457. | KQ1 | 2
Freeman SA. Suicide risk and psychopharmacology: assessment and management of acute and chronic risk factors. J Clin Psychiatry. 2009;70(Issue):1052–1053. | KQ1 | 8
Galfalvy H, Currier D, Oquendo MA, Sullivan G, Huang YY, John Mann J. Lower CSF MHPG predicts short-term risk for suicide attempt. Int J Neuropsychopharmacol. 2009;12(Issue):1327–1335. | KQ1 | 4
Galfalvy H, Huang YY, Oquendo MA, Currier D, Mann JJ. Increased risk of suicide attempt in mood disorders and TPH1 genotype. J Affect Disord. 2009;115(Issue):331–338. | KQ1 | 4
Gammelgard M, Koivisto A-M, Eronen M, Kaltiala-Heino R. Violence risk and psychopathology in institutionalised adolescents. J Forens Psychiatry Psychol. 2010;21(Issue):933–949. | KQ1 | 3
Gao K, Tolliver BK, Kemp DE, et al. Correlates of historical suicide attempt in rapid-cycling bipolar disorder: a cross-sectional assessment. J Clin Psychiatry. 2009;70(Issue):1032–1040. | KQ1 | 4
Garcia-Amador M, Colom F, Valenti M, Horga G, Vieta E. Suicide risk in rapid cycling bipolar patients. J Affect Disord. 2009;117(Issue):74–78. | KQ1 | 4
George MS, Raman R, Benedek DM, et al. A two-site pilot randomized 3 day trial of high dose left prefrontal repetitive transcranial magnetic stimulation (rTMS) for suicidal inpatients. Brain Stimulation. 2014;7(Issue):421–431. | KQ2 | 6
Georgia Regents University, National Institute of Mental Health, Wake Forest School of Medicine, University of Wisconsin Madison, Duke University. Reducing Suicidal Ideation Through Insomnia Treatment (REST-IT). ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01689909. Accessed September 25, 2015. | KQ2 | 8
Georgia Regents University. Reducing Suicidal Ideation Through Treatment of Nightmares-Post Traumatic Stress Disorder (PTSD) (REST-ON PTSD). ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT02199652. Accessed September 25, 2015. | KQ2 | 8
Ghahramanlou-Holloway M, Brown GK, Currier GW, et al. Safety Planning for Military (SAFE MIL): rationale, design, and safety considerations of a randomized controlled trial to reduce suicide risk among psychiatric inpatients. Contemp Clin Trials. 2014;39(Issue):113–123. | KQ2 | 8
Ghahramanlou-Holloway M, Cox DW, Greene FN. Post-admission cognitive therapy: A brief intervention for psychiatric inpatients admitted after a suicide attempt. Cogn Behav Pract. 2012;19(Issue):233–244. | KQ2 | 8
Gilat I, Shahar G. Suicide prevention by online support groups: An action theory-based model of emotional first aid. Arch Suicide Res. 2009;13(Issue):52–63. | KQ2 | 8
Girardi P, Pompili M, Innamorati M, et al. Temperament, post-partum depression, hopelessness, and suicide risk among women soon after delivering. Women Health. 2011;51(Issue):511–524. | KQ1 | 2
Glasner-Edwards S, Mooney LJ, Marinelli-Casey P, et al. Risk Factors for Suicide Attempts in Methamphetamine-Dependent Patients. Am J Addict. 2008;17(Issue):24–27. | KQ1 | 4
Goodman M. High Risk Suicidal Veterans - Predictors of Suicide Risk and Efficacy of Dialectal Behavior Therapy. VISN 3 Mental Illness Research, Education & Clinical Center. http://www.mirecc.va.gov/visn3/clinical.asp#Behavior. Accessed September 25, 2015. | KQ2 | 8^†^
Goodwin RD, Marusic A. Perception of health, suicidal ideation, and suicide attempt among adults in the community. Crisis. 2011;32(Issue):346–351. | KQ1 | 4
Gould MS, Cross W, Pisani AR, Munfakh JL, Kleinman M. Impact of Applied Suicide Intervention Skills Training on the National Suicide Prevention Lifeline. Suicide Life Threat Behav. 2013;43(Issue):676–691. | KQ2 | 6
Gray D, Coon H, McGlade E, et al. Comparative analysis of suicide, accidental, and undetermined cause of death classification. Suicide Life Threat Behav. 2014;44(Issue):304–316. | KQ1 | 4
Green JM, Wood AJ, Kerfoot MJ, et al. Group therapy for adolescents with repeated self harm: randomised controlled trial with economic evaluation. BMJ. 2011;342(Issue). | KQ2 | 3
Group Health Cooperative, National Institute of Mental Health, HealthPartners Institute for Education Research, Kaiser Permanente. UH3 Pragmatic Suicide Prevention Trial. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02326883. Accessed September 25, 2015. | KQ2 | 8
Group Health Cooperative, National Institute of Mental Health. Now Matters Now: An Online Suicide Prevention Program. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01924936. Accessed September 25, 2015. | KQ2 | 8
Grunebaum MF, Ellis SP, Duan N, Burke AK, Oquendo MA, Mann JJ. Pilot randomized clinical trial of an SSRI vs bupropion: Effects on suicidal behavior, ideation, and mood in major depression. Neuropsychopharmacology. 2012;37(Issue):697–706. | KQ1 | 4
Grunebaum MF, Keilp JG, Ellis SP, et al. SSRI versus bupropion effects on symptom clusters in suicidal depression: Post hoc analysis of a randomized clinical trial. J Clin Psychiatry. 2013;74(Issue):872–879. | KQ2 | 4
Guintivano J, Brown T, Newcomer A, et al. Identification and replication of a combined epigenetic and genetic biomarker predicting suicide and suicidal behaviors. Am J Psychiatry. 2014;171(Issue):1287–1296. | KQ1 | 6
Gunn JF, 3rd, Lester D, McSwain S. Testing the warning signs of suicidal behavior among suicide ideators using the 2009 National survey on drug abuse and health. Int J Emerg Ment Health. 2011;13(Issue):147–154. | KQ1 | 4
Gunnarsdottir OS, Rafnsson V. Risk of suicide and fatal drug poisoning after discharge from the emergency department: a nested case-control study. Emerg Med J. 2010;27(Issue):93–96. | KQ1 | 2
Gupta MA. Suicide attempt and externalizing behaviours in posttraumatic stress disorder (PTSD): Possible role of the activating effect of antidepressants. Aust N Z J Psychiatry. 2015;49(Issue):89–90. | KQ2 | 7
Gureje O, Oladeji B, Hwang I, et al. Parental psychopathology and the risk of suicidal behavior in their offspring: results from the World Mental Health surveys. Mol Psychiatry. 2011;16(Issue):1221–1233. | KQ1 | 4
Hamdi E, Price S, Qassem T, Amin Y, Jones D. Suicides not in contact with mental health services: Risk indicators and determinants of referral. J Ment Health. 2008;17(Issue):398–409. | KQ1 | 4
Hampton T. Depression care effort brings dramatic drop in large HMO population’s suicide rate. JAMA. 2010;303(Issue):1903–1905. | KQ2 | 8
Harris KM, McLean JP, Sheffield J. Examining suicide-risk individuals who go online for suicide-related purposes. Arch Suicide Res. 2009;13(Issue):264–276. | KQ1 | 4
Harrison DP, Stritzke WG, Fay N, Ellison TM, Hudaib AR. Probing the implicit suicidal mind: does the Death/Suicide Implicit Association Test reveal a desire to die, or a diminished desire to live? Psychol Assess. 2014;26(Issue):831–840. | KQ1 | 6
Harrod CS, Goss CW, Stallones L, DiGuiseppi C. Interventions for primary prevention of suicide in university and other post-secondary educational settings (Review). Cochrane Database of Systematic Reviews. 2014(Issue). | KQ2 | 9
Hassanian-Moghaddam H, Sarjami S, Kolahi A-A, Carter GL. Postcards in Persia: Randomised controlled trial to reduce suicidal behaviours 12 months after hospital-treated self-poisoning. Br J Psychiatry. 2011;198(Issue):309–316. | KQ2 | 2
Hassiotis A, Tanzarella M, Bebbington P, Cooper C. Prevalence and predictors of suicidal behaviour in a sample of adults with estimated borderline intellectual functioning: results from a population survey. J Affect Disord. 2011;129(Issue):380–384. | KQ1 | 4
Hatcher S, Sharon C, House A, Collins N, Collings S, Pillai A. The ACCESS study: Zelen randomised controlled trial of a package of care for people presenting to hospital after self-harm. Br J Psychiatry. 2015;206(Issue):229–236. | KQ2 | 6
Hawkins KA, Hames JL, Ribeiro JD, Silva C, Joiner TE, Cougle JR. An examination of the relationship between anger and suicide risk through the lens of the interpersonal theory of suicide. J Psychiatr Res. 2014;50(Issue):59–65. | KQ1 | 4
Hazell PL, Martin G, McGill K, et al. Group therapy for repeated deliberate self-harm in adolescents: Failure of replication of a randomized trial. J Am Acad Child Adolesc Psychiatry. 2009;48(Issue):662–670. | KQ2 | 3
Hazlett E, Goodman M. Affective Startle Assessment in High Risk Suicidal Veterans (DoD Supplement). VISN 3 Mental Illness Research, Education & Clinical Center. http://www.mirecc.va.gov/visn3/clinical.asp#Startle. Accessed September 25, 2015. | KQ1 | 8^*^
Health NIoM, N aIoHCC. Ask Suicide-Screening Questions to Everyone in Medical Settings (asQ em): Development of a Suicide Risk Screening Instrument for Adult Medical Inpatients. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02140177. Accessed September 25, 2015. | KQ1 | 8
Hegerl U, Mergl R, Havers I, et al. Sustainable effects on suicidality were found for the Nuremberg alliance against depression. Eur Arch Psychiatry Clin Neurosci. 2010;260(Issue):401–406. | KQ2 | 2
Hegerl U, Wittenburg L, Arensman E, et al. Optimizing Suicide Prevention Programs and Their Implementation in Europe (OSPI Europe): An evidence-based multi-level approach. BMC Public Health. 2009;9(Issue). | KQ2 | 8
Hegerl U, Wittenburg L. The European Alliance Against Depression: A multilevel approach to the prevention of suicidal behavior. Psychiatr Serv. 2009;60(Issue):596–599. | KQ2 | 8
Heisel MJ, Duberstein PR, Lyness JM, Feldman MD. Screening for suicide ideation among older primary care patients. J Am Board Fam Med. 2010;23(Issue):260–269. | KQ1 | 6
Henry M. Jackson Foundation for the Advancement of Military Medicine, U.S. Army Medical Research and Materiel Command, Department of Defense, et al. A Brief Intervention to Reduce Suicide Risk in Military Service Members and Veterans - Study 2 (SAFEMIL). ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01360736. Accessed September 25, 2015. | KQ2 | 8
Henry M. Jackson Foundation for the Advancement of Military Medicine, National Alliance for Research on Schizophrenia and Depression. Inpatient Post Admission Cognitive Therapy (PACT) for the Prevention of Suicide Attempts. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01340859. Accessed September 25, 2015. | KQ2 | 8^†^
Henry M. Jackson Foundation for the Advancement of Military Medicine, Department of Veterans Affairs, Duke University, et al. Post Admission Cognitive Therapy (PACT) for the Inpatient Treatment of Military Personnel With Suicidal Behaviors. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01359761. Accessed September 25, 2015. | KQ2 | 8^†^
Henry M. Jackson Foundation for the Advancement of Military Medicine, Congressionally Directed Medical Research Programs. Pilot Trial of Inpatient Cognitive Therapy for the Prevention of Suicide in Military Personnel. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01356186. Accessed September 25, 2015. | KQ2 | 8^†^
Hills AL, Afifi TO, Cox BJ, Bienvenu OJ, Sareen J. Externalizing psychopathology and risk for suicide attempt: cross-sectional and longitudinal findings from the Baltimore Epidemiologic Catchment Area Study. J Nerv Ment Dis. 2009;197(Issue):293–297. | KQ1 | 4
Hinshaw SP, Owens EB, Zalecki C, et al. Prospective follow-up of girls with attention-deficit/hyperactivity disorder into early adulthood: continuing impairment includes elevated risk for suicide attempts and self-injury. J Consult Clin Psychol. 2012;80(Issue):1041–1051. | KQ1 | 4
Hirsch JK, Duberstein PR, Unutzer J. Chronic medical problems and distressful thoughts of suicide in primary care patients: mitigating role of happiness. Int J Geriatr Psychiatry. 2009;24(Issue):671–679. | KQ2 | 6
Hjorthoj CR, Madsen T, Agerbo E, Nordentoft M. Risk of suicide according to level of psychiatric treatment: A nationwide nested case-control study. Soc Psychiatry Psychiatr Epidemiol. 2014;49(Issue):1357–1365. | KQ1 | 2
Holden C. Psychiatry. Suicide scale. Science. 2010;327(Issue):1068. | KQ1 | 8
Holland JM, Malott J, Currier JM. Meaning made of stress among veterans transitioning to college: examining unique associations with suicide risk and life-threatening behavior. Suicide Life Threat Behav. 2014;44(Issue):218–231. | KQ1 | 4
Holma KM, Melartin TK, Haukka J, Holma IA, Sokero TP, Isometsa ET. Incidence and predictors of suicide attempts in DSM-IV major depressive disorder: a five-year prospective study. Am J Psychiatry. 2010;167(Issue):801–808. | KQ1 | 2
Holtmann M, Buchmann AF, Esser G, Schmidt MH, Banaschewski T, Laucht M. The Child Behavior Checklist-Dysregulation Profile predicts substance use, suicidality, and functional impairment: a longitudinal analysis. J Child Psychol Psychiatry. 2011;52(Issue):139–147. | KQ1 | 2
Hom MA, Stanley IH, Joiner TE. Evaluating factors and interventions that influence help-seeking and mental health service utilization among suicidal individuals: A review of the literature. Clin Psychol Rev. 2015;40(Issue):28–39. | KQ2 | 7
Homaifar B, Amick M. Thinking Under Stress and the Risk of Suicide. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/thinking-under-stress-and-risk-suicide. Accessed September 25, 2015. | KQ1 | 4
Hooven C, Snedker KA, Thompson EA. Suicide Risk at Young Adulthood: Continuities and Discontinuities From Adolescence. Youth & Society. 2012;44(Issue):524–547. | KQ1 | 4
Hopwood CJ, Baker KL, Morey LC. Extratest validity of selected personality assessment inventory scales and indicators in an inpatient substance abuse setting. J Pers Assess. 2008;90(Issue):574–577. | KQ1 | 4
Horesh N, Levi Y, Apter A. Medically serious versus non-serious suicide attempts: relationships of lethality and intent to clinical and interpersonal characteristics. J Affect Disord. 2012;136(Issue):286–293. | KQ1 | 4
Horowitz LM, Bridge JA, Teach SJ, et al. Ask Suicide-Screening Questions (ASQ): a brief instrument for the pediatric emergency department. Arch Pediatr Adolesc Med. 2012;166(Issue):1170–1176. | KQ1 | 3
Hovanesian S, Isakov I, Cervellione KL. Defense mechanisms and suicide risk in major depression. Arch Suicide Res. 2009;13(Issue):74–86. | KQ1 | 4
Hoyer EH, Licht RW, Mortensen PB. Risk factors of suicide in inpatients and recently discharged patients with affective disorders. A case-control study. Eur Psychiatry. 2009;24(Issue):317–321. | KQ1 | 2
Huber CG, Schottle D, Lambert M, et al. Brief Psychiatric Rating Scale - Excited Component (BPRS-EC) and neuropsychological dysfunction predict aggression, suicidality, and involuntary treatment in first-episode psychosis. Schizophr Res. 2012;134(Issue):273–278. | KQ1 | 2
Hung GC, Caine ED, Fan HF, Huang MC, Chen YY. Predicting suicide attempts among treatment-seeking male alcoholics: an exploratory study. Suicide Life Threat Behav. 2013;43(Issue):429–438. | KQ1 | 2
Hunt IM, Kapur N, Webb R, et al. Suicide in recently discharged psychiatric patients: a case-control study. Psychol Med. 2009;39(Issue):443–449. | KQ1 | 4
Hunter A, Leuchter A, Cook I, Abrams M. Brain functional changes (QEEG cordance) and worsening suicidal ideation and mood symptoms during antidepressant treatment. Acta Psychiatr Scand. 2010;122(Issue):461–469. | KQ1 | 6
Hvid M, Wang AG. Preventing repetition of attempted suicide--I. Feasibility (acceptability, adherence, and effectiveness) of a Baerum-model like aftercare. Nord J Psychiatry. 2009;63(Issue):148–153. | KQ2 | 2
Hyman J, Ireland R, Frost L, Cottrell L. Suicide incidence and risk factors in an active duty US military population. Am J Public Health. 2012;102 Suppl 1(Issue):S138–146. | KQ1 | 4
Ichikawa M, Inada H, Kumeji M. Reconsidering the effects of blue-light installation for prevention of railway suicides. J Affect Disord.152(Issue):183–185. | KQ2 | 2
Ilgen MA, Bohnert AS, Ignacio RV, et al. Psychiatric diagnoses and risk of suicide in veterans. Arch Gen Psychiatry. 2010;67(Issue):1152–1158. | KQ1 | 4
Ilgen MA, Downing K, Zivin K, et al. Exploratory data mining analysis identifying subgroups of patients with depression who are at high risk for suicide. J Clin Psychiatry. 2009;70(Issue):1495–1500. | KQ1 | 4
Innamorati M, Pompili M, Serafini G, et al. Psychometric properties of the suicidal history self-rating screening scale. Arch Suicide Res. 2011;15(Issue):87–92. | KQ1 | 2
Iosifescu D, Greenwald S, Devlin P, et al. Pretreatment frontal EEG and changes in suicidal ideation during SSRI treatment in major depressive disorder. Acta Psychiatr Scand. 2008;117(Issue):271–276. | KQ1 | 6
Isaac M, Elias B, Katz LY, et al. Gatekeeper training as a preventative intervention for suicide: A systematic review. Can J Psychiatry. 2009;54(Issue):260–268. | KQ2 | 9
Isacsson G, Holmgren A, Osby U, Ahlner J. Decrease in suicide among the individuals treated with antidepressants: a controlled study of antidepressants in suicide, Sweden 1995–2005. Acta Psychiatr Scand. 2009;120(Issue):37–44. | KQ2 | 2
Jandl M, Steyer J, Kaschka WP. Suicide risk markers in major depressive disorder: a study of electrodermal activity and event-related potentials. J Affect Disord. 2010;123(Issue):138–149. | KQ1 | 2
Janelidze S, Suchankova P, Ekman A, et al. Low il-8 is associated with anxiety in suicidal patients: Genetic variation and decreased protein levels. Acta Psychiatr Scand. 2015;131(Issue):269–278. | KQ1 | 2
Janssen Research & Development LLC. A Double-blind Study to Assess the Efficacy and Safety of Intranasal Esketamine for the Rapid Reduction of the Symptoms of Major Depressive Disorder, Including Suicidal Ideation, in Participants Who Are Assessed to be at Imminent Risk for Suicide. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02133001. Accessed September 25, 2015. | KQ2 | 6
Jobes DA. Innovations in Clinical Assessment and Treatment of Suicide Risk. Paper presented at: Texas Suicide Prevention Symposium: Coming Together to Care 20152015; Houston, TX. | KQ1 & KQ2 | 8
Joe S, Canetto SS, Romer D. Advancing prevention research on the role of culture in suicide prevention. Suicide Life Threat Behav. 2008;38(Issue):354–362. | KQ2 | 8
Johnson JG, Zhang B, Prigerson HG. Investigation of a developmental model of risk for depression and suicidality following spousal bereavement. Suicide Life Threat Behav. 2008;38(Issue):1–12. | KQ1 | 4
Johnson LL, O’Connor SS, Kaminer B, Jobes DA, Gutierrez PM. Suicide-Focused Group Therapy for Veterans. Mil Behav Health. 2014;2(Issue):327–336. | KQ2 | 8
Joiner TE, Gutierrez PM. Toward a Gold Standard for Suicide Risk Assessment for Military Personnel. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/toward-gold-standard-suicide-risk-assessment-military-personnel. Accessed September 25, 2015. | KQ1 | 8^*^
Joiner TE, Jr., Van Orden KA, Witte TK, et al. Main predictions of the interpersonal-psychological theory of suicidal behavior: empirical tests in two samples of young adults. J Abnorm Psychol. 2009;118(Issue):634–646. | KQ1 | 4
Jokinen J, Chatzittofis A, Hellstrom C, Nordstrom P, Uvnas-Moberg K, Asberg M. Low CSF oxytocin reflects high intent in suicide attempters. Psychoneuroendocrinology. 2012;37(Issue):482–490. | KQ1 | 2
Jokinen J, Forslund K, Ahnemark E, Gustavsson JP, Nordstrom P, Asberg M. Karolinska Interpersonal Violence Scale predicts suicide in suicide attempters. J Clin Psychiatry. 2010;71(Issue):1025–1032. | KQ1 | 2
Jokinen J, Nordstrom AL, Nordstrom P. CSF 5-HIAA and DST non-suppression--orthogonal biologic risk factors for suicide in male mood disorder inpatients. Psychiatry Res. 2009;165(Issue):96–102. | KQ1 | 2
Jokinen J, Ouda J, Nordstrom P. Noradrenergic function and HPA axis dysregulation in suicidal behaviour. Psychoneuroendocrinology. 2010;35(Issue):1536–1542. | KQ1 | 2
Kaplan MS, McFarland BH, Huguet N, Valenstein M. Suicide risk and precipitating circumstances among young, middle-aged, and older male veterans. Am J Public Health. 2012;102 Suppl 1(Issue):S131–137. | KQ1 | 4
Kapur N, Murphy E, Cooper J, et al. Psychosocial assessment following self-harm: results from the multi-centre monitoring of self-harm project. J Affect Disord. 2008;106(Issue):285–293. | KQ1 | 6
Karras E, Stephens B, Kemp JE, Bossarte RM. Using media to promote suicide prevention hotlines to Veteran households. Inj Prev. 2014;20(Issue):62–65. | KQ2 | 6
Kashyap S, Hooke GR, Page AC. Identifying risk of deliberate self-harm through longitudinal monitoring of psychological distress in an inpatient psychiatric population. BMC Psychiatry. 2015;15(Issue):81. | KQ1 | 4
Kasper S, Montgomery SA, Moller H-J, et al. Longitudinal analysis of the suicidal behaviour risk in short-term placebo-controlled studies of mirtazapine in major depressive disorder. World J Biol Psychiatry. 2010;11(Issue):36–44. | KQ1 | 4
Kessler RC, Santiago PN, Colpe LJ, et al. Clinical reappraisal of the Composite International Diagnostic Interview Screening Scales (CIDI-SC) in the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS). Int J Methods Psychiatr Res. 2013;22(Issue):303–321. | KQ1 | 4
Khalsa HM, Salvatore P, Hennen J, Baethge C, Tohen M, Baldessarini RJ. Suicidal events and accidents in 216 first-episode bipolar I disorder patients: predictive factors. J Affect Disord. 2008;106(Issue):179–184. | KQ1 | 4
Khan A, Khan SR, Hobus J, et al. Differential pattern of response in mood symptoms and suicide risk measures in severely ill depressed patients assigned to citalopram with placebo or citalopram combined with lithium: role of lithium levels. J Psychiatr Res. 2011;45(Issue):1489–1496. | KQ2 | 4
Kim YK, Hwang JA, Lee HJ, et al. Association between norepinephrine transporter gene (SLC6A2) polymorphisms and suicide in patients with major depressive disorder. J Affect Disord. 2014;158(Issue):127–132. | KQ1 | 2
King CA, Eisenberg D, Zheng K, et al. Online suicide risk screening and intervention with college students: A pilot randomized controlled trial. J Consult Clin Psychol. 2015;83(Issue):630–636. | KQ2 | 6
King CA, Klaus N, Kramer A, Venkataraman S, Quinlan P, Gillespie B. The Youth-Nominated Support Team-Version II for suicidal adolescents: A randomized controlled intervention trial. J Consult Clin Psychol. 2009;77(Issue):880–893. | KQ2 | 3
Klieve H, Barnes M, De Leo D. Controlling firearms use in Australia: has the 1996 gun law reform produced the decrease in rates of suicide with this method? Soc Psychiatry Psychiatr Epidemiol. 2009;44(Issue):285–292. | KQ2 | 7
Klomek AB, Kleinman M, Altschuler E, Marrocco F, Amakawa L, Gould MS. High school bullying as a risk for later depression and suicidality. Suicide Life Threat Behav. 2011;41(Issue):501–516. | KQ1 | 4
Klonsky ED, Glenn CR. Assessing the Functions of Non-suicidal Self-injury: Psychometric Properties of the Inventory of Statements About Self-injury (ISAS). J Psychopathol Behav Assess. 2009;31(Issue):215–219. | KQ1 | 6
Klonsky ED, Olino TM. Identifying clinically distinct subgroups of self-injurers among young adults: a latent class analysis. J Consult Clin Psychol. 2008;76(Issue):22–27. | KQ1 | 6
Kmietowicz Z. Older people who self harm need long term follow-up to reduce suicide risk. BMJ. 2012;344(Issue):e3120. | KQ2 | 8
Kovacsics CE, Goyal HK, Thomas KJ, Gould TD. The antisuicidal efficacy of lithium: A review of the clinical literature and the underlying pharmacology. Int J Child Health Hum Dev. 2008;1(Issue):225–243. | KQ2 | 8
Krysinska K, Martin G. The struggle to prevent and evaluate: Application of population attributable risk and preventive fraction to suicide prevention research. Suicide Life Threat Behav. 2009;39(Issue):548–557. | KQ2 | 8
Kurd SK, Troxel AB, Crits-Christoph P, Gelfand JM. The risk of depression, anxiety, and suicidality in patients with psoriasis: a population-based cohort study. Arch Dermatol. 2010;146(Issue):891–895. | KQ1 | 4
Labonte B, Suderman M, Maussion G, et al. Genome-wide epigenetic regulation by early-life trauma. Arch Gen Psychiatry. 2012;69(Issue):722–731. | KQ1 | 4
Labonte B, Yerko V, Gross J, et al. Differential glucocorticoid receptor exon 1(B), 1(C), and 1(H) expression and methylation in suicide completers with a history of childhood abuse. Biol Psychiatry. 2012;72(Issue):41–48. | KQ1 | 6
Lam BL, Christ SL, Lee DJ, Zheng DD, Arheart KL. Reported visual impairment and risk of suicide: the 1986–1996 national health interview surveys. Arch Ophthalmol. 2008;126(Issue):975–980. | KQ1 | 4
Langley J, Gehrs M, Wasylenki D, Dewa C, Rueda S, Rourke S. Suicidality in Seriously Mentally Ill Clients of Two Intensive Community Mental Health Programs. Can J Commun Ment Health. 2009;28(Issue):151–164. | KQ2 | 6
Lapierre S, Erlangsen A, Waern M, et al. A systematic review of elderly suicide prevention programs. Crisis. 2011;32(Issue):88–98. | KQ2 | 9
Large M, Ryan C, Nielssen O. The validity and utility of risk assessment for inpatient suicide. Australasian Psychiatry. 2011;19(Issue):507–512. | KQ1 | 9
Lauterbach E, Felber W, Muller-Oerlinghausen B, et al. Adjunctive lithium treatment in the prevention of suicidal behaviour in depressive disorders: a randomised, placebo-controlled, 1-year trial. Acta Psychiatr Scand. 2008;118(Issue):469–479. | KQ2 | 2
Lavigne JE, McCarthy M, Chapman R, Petrilla A, Knox KL. Exposure to prescription drugs labeled for risk of adverse effects of suicidal behavior or ideation among 100 Air Force personnel who died by suicide, 2006–2009. Suicide Life Threat Behav. 2012;42(Issue):561–566. | KQ1 | 4
LeardMann CA, Powell TM, Smith TC, et al. Risk factors associated with suicide in current and former US military personnel. JAMA. 2013;310(Issue):496–506. | KQ1 | 4
Lee BH, Kim YK. Potential peripheral biological predictors of suicidal behavior in major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. 2011;35(Issue):842–847. | KQ1 | 4
Lee J, Hahm HC. HIV Risk, Substance Use, and Suicidal Behaviors Among Asian American Lesbian and Bisexual Women. AIDS Educ Prev. 2012;24(Issue):549–563. | KQ1 | 4
Legris J, Links PS, van Reekum R, Tannock R, Toplak M. Executive function and suicidal risk in women with Borderline Personality Disorder. Psychiatry Res. 2012;196(Issue):101–108. | KQ1 | 6
Lesser I, Rosales A, Zisook S, et al. Depression outcomes of Spanish- and english-speaking Hispanic outpatients in STAR*D. Psychiatr Serv. 2008;59(Issue):1273–1284. | KQ2 | 6
Lester D, McSwain S, Gunn JF, 3rd. A test of the validity of the IS PATH WARM warning signs for suicide. Psychol Rep. 2011;108(Issue):402–404. | KQ1 | 7
Lester D. The Use of the Internet for Counseling the Suicidal Individual: Possibilities and Drawbacks. Omega (Westport). 2008;58(Issue):233–250. | KQ2 | 8
Li H, Xie W, Luo X, et al. Clarifying the role of psychological pain in the risks of suicidal ideation and suicidal acts among patients with major depressive episodes. Suicide Life Threat Behav. 2014;44(Issue):78–88. | KQ1 | 2
Li Y, Zhang J, McKeown RE. Cross-sectional assessment of diet quality in individuals with a lifetime history of attempted suicide. Psychiatry Res. 2009;165(Issue):111–119. | KQ1 | 4
Lineberry TW, Allen JD, Nash J, Galardy CW. Population-based prevalence of smoking in psychiatric inpatients: a focus on acute suicide risk and major diagnostic groups. Compr Psychiatry. 2009;50(Issue):526–532. | KQ1 | 4
Links PS, Bergmans Y, Cook M. Psychotherapeutic Interventions to Prevent Repeated Suicidal Behavior. Brief Treatment and Crisis Intervention. 2003;3(Issue):445–464. | KQ1 | 8
Lizardi D, Dervic K, Grunebaum MF, Burke AK, Mann JJ, Oquendo MA. The role of moral objections to suicide in the assessment of suicidal patients. J Psychiatr Res. 2008;42(Issue):815–821. | KQ1 | 4
Lizardi D, Stanley B. Treatment engagement: A neglected aspect in the psychiatric care of suicidal patients. Psychiatr Serv. 2010;61(Issue):1183–1191. | KQ2 | 6
Logan J, Hall J, Karch D. Suicide categories by patterns of known risk factors: a latent class analysis. Arch Gen Psychiatry. 2011;68(Issue):935–941. | KQ1 | 4
Love J, Zatzick D. Screening and intervention for comorbid substance disorders, PTSD, depression, and suicide: A trauma center survey. Psychiatr Serv. 2014;65(Issue):918–923. | KQ1 | 4
Lubin G, Werbeloff N, Halperin D, Shmushkevitch M, Weiser M, Knobler HY. Decrease in suicide rates after a change of policy reducing access to firearms in adolescents: a naturalistic epidemiological study. Suicide Life Threat Behav. 2010;40(Issue):421–424. | KQ2 | 2
Luxton DD, June JD, Comtois KA. Can postdischarge follow-up contacts prevent suicide and suicidal behavior? A review of the evidence. Crisis. 2013;34(Issue):32–41. | KQ2 | 9
Luxton DD, Kinn JT, June JD, Pierre LW, Reger MA, Gahm GA. Caring Letters Project: a military suicide-prevention pilot program. Crisis. 2012;33(Issue):5–12. | KQ2 | 7
Luxton DD, Rudd MD, Reger MA, Gahm GA. A psychometric study of the Suicide Ideation Scale. Arch Suicide Res. 2011;15(Issue):250–258. | KQ1 | 6
Luxton DD, Thomas EK, Chipps J, et al. Caring letters for suicide prevention: Implementation of a multi-site randomized clinical trial in the U.S. military and veteran affairs healthcare systems. Contemp Clin Trials. 2014;37(Issue):252–260. | KQ2 | 8
Lyddon R, Dwork AJ, Keddache M, Siever LJ, Dracheva S. Serotonin 2c receptor RNA editing in major depression and suicide. World J Biol Psychiatry. 2013;14(Issue):590–601. | KQ1 | 4
Lynch SM, Forman E, Mendelsohn M, Herman J. Attending to Dissociation: Assessing Change in Dissociation and Predicting Treatment Outcome. J Trauma Dissociation. 2008;9(Issue):301–319. | KQ1 | 6
Magno LA, Miranda DM, Neves FS, et al. Association between AKT1 but not AKTIP genetic variants and increased risk for suicidal behavior in bipolar patients. Genes Brain Behav. 2010;9(Issue):411–418. | KQ1 | 2
Malloy-Diniz LF, Neves FS, Abrantes SS, Fuentes D, Correa H. Suicide behavior and neuropsychological assessment of type I bipolar patients. J Affect Disord. 2009;112(Issue):231–236. | KQ1 | 4
Maloney E, Degenhardt L, Darke S, Nelson EC. Impulsivity and borderline personality as risk factors for suicide attempts among opioid-dependent individuals. Psychiatry Res. 2009;169(Issue):16–21. | KQ1 | 4
Marshall E, York J, Magruder K, et al. Implementation of online suicide-specific training for VA providers. Acad Psychiatry. 2014;38(Issue):566–574. | KQ2 | 6
Massachusetts General H. Development of a Positive Psychology Intervention to Reduce Suicide Risk (HOPE). ClinicalTrials.gov. 2013; https://ClinicalTrials.gov/show/NCT01398891. Accessed September 25, 2015. | KQ2 | 8
Massachusetts General Hospital, American Foundation for Suicide Prevention. Intranasal Ketamine for Late-Life Depression and Suicidal Ideation. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02295787. Accessed September 25, 2015. | KQ2 | 8
Massachusetts General Hospital, American Foundation for Suicide Prevention. Trial of a Positive Psychology Intervention in Major Depressive Disorder (HOPE). ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT02004145. Accessed September 25, 2015. | KQ2 | 8
Massachusetts General Hospital, American Foundation for Suicide Prevention. Brief Sleep Intervention for Bipolar Disorder. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01764074. Accessed September 25, 2015. | KQ2 | 8
Matarazzo B. Improving the Inpatient-to-Outpatient Transition. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/improving-inpatient-outpatient-transition. Accessed September 25, 2015. | KQ2 | 8^†^
Matarazzo BB, Hoffberg AS, Clemans TA, Signoracci GM, Simpson GK, Brenner LA. Cross-cultural adaptation of the Window to Hope: a psychological intervention to reduce hopelessness among U.S. veterans with traumatic brain injury. Brain Inj. 2014;28(Issue):1238–1247. | KQ2 | 8
Matsubayashi T, Ueda M. The effect of national suicide prevention programs on suicide rates in 21 OECD nations. Soc Sci Med. 2011;73(Issue):1395–1400. | KQ2 | 2
Matthews S, Spadoni A, Knox K, Strigo I, Simmons A. Combat-exposed war veterans at risk for suicide show hyperactivation of prefrontal cortex and anterior cingulate during error processing. Psychosom Med. 2012;74(Issue):471–475. | KQ1 | 6
Matthieu MM, Chen Y, Schohn M, Lantinga LJ, Knox KL. Educational preferences and outcomes from suicide prevention training in the Veterans Health Administration: one-year follow-up with healthcare employees in Upstate New York. Mil Med. 2009;174(Issue):1123–1131. | KQ2 | 6
Matthieu MM, Cross W, Batres AR, Flora CM, Knox KL. Evaluation of gatekeeper training for suicide prevention in veterans. Arch Suicide Res. 2008;12(Issue):148–154. | KQ2 | 6
Maussion G, Yang J, Yerko V, et al. Regulation of a truncated form of tropomyosin-related kinase B (TrkB) by Hsa-miR-185* in frontal cortex of suicide completers. PLoS One. 2012;7(Issue):e39301. | KQ1 | 4
May AM, Klonsky ED, Klein DN. Predicting future suicide attempts among depressed suicide ideators: a 10-year longitudinal study. J Psychiatr Res. 2012;46(Issue):946–952. | KQ1 | 4
May AM, Klonsky ED. Assessing motivations for suicide attempts: development and psychometric properties of the inventory of motivations for suicide attempts. Suicide Life Threat Behav. 2013;43(Issue):532–546. | KQ1 | 4
Mayo Clinic. Ketamine for Depression and Suicide Risk. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02094898. Accessed September 25, 2015. | KQ2 | 8
McCarthy JF, Blow FC, Ignacio RV, Ilgen MA, Austin KL, Valenstein M. Suicide Among Patients in the Veterans Affairs Health System: Rural-Urban Differences in Rates, Risks, and Methods. Am J Public Health. 2012;102(Issue):S111–S117. | KQ1 | 4
McCloskey MS, Ben-Zeev D, Lee R, Berman ME, Coccaro EF. Acute tryptophan depletion and self-injurious behavior in aggressive patients and healthy volunteers. Psychopharmacology (Berl). 2009;203(Issue):53–61. | KQ1 | 6
McGirr A, Alda M, Seguin M, Cabot S, Lesage A, Turecki G. Familial aggregation of suicide explained by cluster B traits: a three-group family study of suicide controlling for major depressive disorder. Am J Psychiatry. 2009;166(Issue):1124–1134. | KQ1 | 4
McGirr A, Diaconu G, Berlim MT, et al. Dysregulation of the sympathetic nervous system, hypothalamic-pituitary-adrenal axis and executive function in individuals at risk for suicide. J Psychiatry Neurosci. 2010;35(Issue):399–408. | KQ1 | 6
McGirr A, Dombrovski AY, Butters MA, Clark L, Szanto K. Deterministic learning and attempted suicide among older depressed individuals: cognitive assessment using the Wisconsin Card Sorting Task. J Psychiatr Res. 2012;46(Issue):226–232. | KQ1 | 4
McGirr A, Paris J, Lesage A, Renaud J, Turecki G. An examination of DSM-IV borderline personality disorder symptoms and risk for death by suicide: a psychological autopsy study. Can J Psychiatry. 2009;54(Issue):87–92. | KQ1 | 4
McGrath PJ, Khan AY, Trivedi MH, et al. Response to a selective serotonin reuptake inhibitor (citalopram) in major depressive disorder with melancholic features: A STAR*D report. J Clin Psychiatry. 2008;69(Issue):1847–1855. | KQ2 | 4
McMain SF, Links PS, Gnam WH, et al. A randomized trial of dialectical behavior therapy versus general psychiatric management for borderline personality disorder. Am J Psychiatry. 2009;166(Issue):1365–1374. | KQ2 | 6
McNulty J, Olsne MA. Improving Marriages to Decrease Suicide Risk. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/improving-marriages-decrease-suicide-risk. Accessed September 25, 2015. | KQ2 | 8
Medical University of South C, Research USAM, Materiel C. The Better Resiliency Among Veterans With Omega-3’s (BRAVO) Study. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01901887. Accessed September 25, 2015. | KQ2 | 6
Mehl-Madrona L, Jul E, Mainguy B. Results of a transpersonal, narrative, and phenomenological psychotherapy for psychosis. International Journal of Transpersonal Studies. 2014;33(Issue):57–76. | KQ2 | 6
Mental Health Services in the Capital Region of Denmark, Lundbeck Foundation, University of Copenhagen. Efficacy of Dialectical Behavior Therapy Versus CAMS-informed Supportive Psychotherapy on Self Harming Behavior (DiaS). ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01512602. Accessed September 25, 2015. | KQ2 | 2
Mezuk B, Larkin GL, Prescott MR, et al. The influence of a major disaster on suicide risk in the population. J Trauma Stress. 2009;22(Issue):481–488. | KQ1 | 4
Michigan Uo, Abuse NIoD. Developing an Intervention to Address Suicide Risk During Substance Use Disorder. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01127932. Accessed September 25, 2015. | KQ2 | 8
Mihaljevic S, Vuksan-Cusa B, Marcinko D, Koic E, Kusevic Z, Jakovljevic M. Spiritual well-being, cortisol, and suicidality in Croatian war veterans suffering from PTSD. J Relig Health. 2011;50(Issue):464–473. | KQ1 | 2
Miller M, Hempstead K, Nguyen T, Barber C, Rosenberg-Wohl S, Azrael D. Method choice in nonfatal self-harm as a predictor of subsequent episodes of self-harm and suicide: implications for clinical practice. Am J Public Health. 2013;103(Issue):e61–68. | KQ1 | 4
Miller M, Pate V, Swanson SA, Azrael D, White A, Sturmer T. Antidepressant class, age, and the risk of deliberate self-harm: a propensity score matched cohort study of SSRI and SNRI users in the USA. CNS Drugs. 2014;28(Issue):79–88. | KQ2 | 4
Miller M, Swanson SA, Azrael D, Pate V, Sturmer T. Antidepressant dose, age, and the risk of deliberate self-harm. JAMA Intern Med. 2014;174(Issue):899–909. | KQ1 | 4
Mills PD, Watts B, Miller S, et al. A checklist to identify inpatient suicide hazards in Veterans Affairs hospitals. Joint Commission Journal on Quality and Patient Safety. 2010;36(Issue):87–93. | KQ1 | 4
Milner A, Page K, Spencer-Thomas S, Lamotagne AD. Workplace suicide prevention: A systematic review of published and unpublished activities. Health Prom Int. 2015;30(Issue):29–37. | KQ2 | 9
Milner AJ, Carter G, Pirkis J, Robinson J, Spittal MJ. Letters, green cards, telephone calls and postcards: systematic and meta-analytic review of brief contact interventions for reducing self-harm, suicide attempts and suicide. Br J Psychiatry. 2015;206(Issue):184–190. | KQ2 | 9
Mishara BL. Reconciling clinical experience with evidence-based knowledge in suicide prevention policy and practice. Crisis. 2008;29(Issue):1–3. | KQ2 | 7
Misson H, Mathieu F, Jollant F, et al. Factor analyses of the Suicidal Intent Scale (SIS) and the Risk-Rescue Rating Scale (RRRS): toward the identification of homogeneous subgroups of suicidal behaviors. J Affect Disord. 2010;121(Issue):80–87. | KQ1 | 2
Mohamed S, Rosenheck R, Cuerdon T. Who terminates from ACT and why? Data from the National VA Mental Health Intensive Case Management Program. Psychiatr Serv. 2010;61(Issue):675–683. | KQ2 | 4
Mollan KR, Smurzynski M, Eron JJ, et al. Association between efavirenz as initial therapy for HIV-1 infection and increased risk for suicidal ideation or attempted or completed suicide: an analysis of trial data. Ann Intern Med. 2014;161(Issue):1–10. | KQ2 | 4
Morley KC, Sitharthan G, Haber PS, Tucker P, Sitharthan T. The efficacy of an opportunistic cognitive behavioral intervention package (OCB) on substance use and comorbid suicide risk: A multisite randomized controlled trial. J Consult Clin Psychol. 2014;82(Issue):130–140. | KQ2 | 6
Morriss R, Kapur N, Byng R. Assessing risk of suicide or self harm in adults. BMJ. 2013;347(Issue):f4572. | KQ1 | 7
Morthorst B, Krogh J, Erlangsen A, Alberdi F, Nordentoft M. Effect of assertive outreach after suicide attempt in the AID (assertive intervention for deliberate self harm) trial: randomised controlled trial. BMJ. Aug 2012;345(Issue):e4972. | KQ2 | 2
Mrnak-Meyer J, Tate SR, Tripp JC, Worley MJ, Jajodia A, McQuaid JR. Predictors of suicide-related hospitalization among U.S. veterans receiving treatment for comorbid depression and substance dependence: who is the riskiest of the risky? Suicide Life Threat Behav. 2011;41(Issue):532–542. | KQ1 | 6
Mukamal KJ, Miller M. BMI and risk factors for suicide: why is BMI inversely related to suicide? Obesity (Silver Spring). 2009;17(Issue):532–538. | KQ1 | 4
Mukamal KJ, Rimm EB, Kawachi I, O’Reilly EJ, Calle EE, Miller M. Body mass index and risk of suicide among one million US adults. Epidemiology. 2010;21(Issue):82–86. | KQ1 | 4
Mula M, Jauch R, Cavanna A, et al. Manic/hypomanic symptoms and quality of life measures in patients with epilepsy. Seizure. 2009;18(Issue):530–532. | KQ1 | 4
Mulder RT, Joyce PR, Frampton CM, Luty SE. Antidepressant treatment is associated with a reduction in suicidal ideation and suicide attempts. Acta Psychiatr Scand. 2008;118(Issue):116–122. | KQ2 | 4
Muller B, Georgi K, Schnabel A, Schneider B. Does sport have a protective effect against suicide? Epidemiol Psichiatr Soc. 2009;18(Issue):331–335. | KQ1 | 2
Muller-Oerlinghausen B, Lewitzka U. Lithium reduces pathological aggression and suicidality: A mini-review. Neuropsychobiology. 2010;62(Issue):43–49. | KQ2 | 8
Murphy E, Kapur N, Webb R, Cooper J. Risk assessment following self-harm: comparison of mental health nurses and psychiatrists. J Adv Nurs. 2011;67(Issue):127–139. | KQ1 | 6
Murphy TM, Ryan M, Foster T, et al. Risk and protective genetic variants in suicidal behaviour: association with SLC1A2, SLC1A3, 5-HTR1B &NTRK2 polymorphisms. Behav Brain Funct. 2011;7(Issue):22. | KQ1 | 2
Murrough J, Medicine MSSo. Ketamine For Suicidal Ideation. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01507181. Accessed September 25, 2015. | KQ2 | 8
Mustanski B, Andrews R, Herrick A, Schnarrs PW, Stall R. A Syndemic of Psychosocial Health Disparities and Associations With Risk for Attempting Suicide Among Young Sexual Minority Men. Am J Public Health. 2014;104(Issue):287–294. | KQ1 | 4
Nademin E, Jobes DA, Pflanz SE, et al. An investigation of interpersonal-psychological variables in air force suicides: a controlled-comparison study. Arch Suicide Res. 2008;12(Issue):309–326. | KQ1 | 6
Najavits LM. Assessment of Risk for Suicide, Violence and Related High-Risk Behaviors in Veterans. VA Health Services Research & Development. 2015; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702991. Accessed September 25, 2015. | KQ1 | 8^*^
National Center for Telehealth and Technology, Department of Defense, U. S. Army Medical Research and Materiel Command. Caring Letters for Military Suicide Prevention. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01473771. Accessed September 25, 2015. | KQ2 | 8^†^
National Center for Telehealth and Technology, The Geneva Foundation, Portland V. A. Medical Center. Virtual Hope Box - Effectiveness of a Smartphone App for Coping With Suicidal Ideation. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01982773. Accessed September 25, 2015. | KQ2 | 8^†^
National Institute of Mental Health, Boston Childrens Hospital, Childrens National Medical Center, Nationwide Childrens Hospital in Columbus Ohio, National Institutes of Health Clinical Center. Validation of the Ask Suicide-Screening Questions (ASQ) in the Inpatient Medical Setting. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT02050867. Accessed September 25, 2015. | KQ1 | 3
Naylor JC, Dolber TR, Strauss JL, et al. A pilot randomized controlled trial with paroxetine for subthreshold PTSD in Operation Enduring Freedom/Operation Iraqi Freedom era veterans. Psychiatry Res. 2013;206(Issue):318–320. | KQ2 | 4
Neely LL, Irwin K, Ponce J, Perera K, Grammer G, Ghahramanlou-Holloway M. Post-Admission Cognitive Therapy (PACT) for the prevention of suicide in military personnel with histories of trauma: Treatment development and case example. Clin Case Stud. 2013;12(Issue):457–473. | KQ2 | 7
Nelson C, Johnston M, Shrivastava A. Improving risk assessment with suicidal patients: a preliminary evaluation of the clinical utility of the Scale for Impact of Suicidality--Management, Assessment and Planning of Care (SIS-MAP). Crisis. 2010;31(Issue):231–237. | KQ1 | 4
Neves FS, Malloy-Diniz LF, Romano-Silva MA, Aguiar GC, de Matos LO, Correa H. Is the serotonin transporter polymorphism (5-HTTLPR) a potential marker for suicidal behavior in bipolar disorder patients? J Affect Disord. 2010;125(Issue):98–102. | KQ1 | 2
New SAMHSA Study on Link Between Suicide and Substance Abuse. Policy & Practice (19426828). 2008;66(Issue):8–8. | KQ1 | 8
New York State Psychiatric Institute, Brain & Behavior Research Foundation. Ketamine for Suicidality in Bipolar Depression. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01944293. Accessed September 25, 2015. | KQ2 | 8
New York State Psychiatric Institute, National Institute of Mental Health. Ketamine in the Treatment of Suicidal Depression. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01700829. Accessed September 25, 2015. | KQ2 | 8
Nierenberg AA, Sylvia LG, Leon AC, et al. Lithium treatment -- moderate dose use study (LiTMUS) for bipolar disorder: rationale and design. Clin Trials. 2009;6(Issue):637–648. | KQ2 | 8
Niner S, Pirkis J, Krysinska K, et al. Research priorities in suicide prevention: A qualitative study of stakeholders’ views. AeJAMH (Australian e-Journal for the Advancement of Mental Health). 2009;8(Issue):1–9. | KQ2 | 7
Nisenbaum R, Links PS, Eynan R, Heisel MJ. Variability and predictors of negative mood intensity in patients with borderline personality disorder and recurrent suicidal behavior: multilevel analyses applied to experience sampling methodology. J Abnorm Psychol. 2010;119(Issue):433–439. | KQ1 | 4
Nkansah-Amankra S, Diedhiou A, Agbanu SK, Agbanu HL, Opoku-Adomako NS, Twumasi-Ankrah P. A longitudinal evaluation of religiosity and psychosocial determinants of suicidal behaviors among a population-based sample in the United States. J Affect Disord. 2012;139(Issue):40–51. | KQ1 | 4
Nkansah-Amankra S. Adolescent suicidal trajectories through young adulthood: prospective assessment of religiosity and psychosocial factors among a population-based sample in the United States. Suicide Life Threat Behav. 2013;43(Issue):439–459. | KQ1 | 4
Nock M. Looking for Cognitive Differences in Suicidal Veterans. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/looking-cognitive-differences-suicidal-veterans. Accessed September 25, 2015. | KQ1 | 8^*^
Nock MK, Banaji MR. Prediction of suicide ideation and attempts among adolescents using a brief performance-based test. J Consult Clin Psychol. 2007;75(Issue):707–715. | KQ1 | 3
Nock MK, Borges G, Bromet EJ, et al. Cross-national prevalence and risk factors for suicidal ideation, plans and attempts. Br J Psychiatry. 2008;192(Issue):98–105. | KQ1 | 4
Nock MK, Stein MB, Heeringa SG, et al. Prevalence and correlates of suicidal behavior among soldiers: results from the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS). JAMA Psychiatry. 2014;71(Issue):514–522. | KQ1 | 4
Norquist GS. Introduction to the STAR*D special section. Psychiatr Serv. 2009;60(Issue):1437–1438. | KQ2 | 8
O’Connor E, Gaynes, B, Burda, BU, Williams, C, Whitlock, EP. Screening for suicide risk in primary care: a systematic evidence review for the U.S. Preventive Services Task Force. Agency for Healthcare Research and Quality (AHRQ);2013. | KQ1 & KQ2 | 9
O’Connor RC, Smyth R, Ferguson E, Ryan C, Williams JM. Psychological processes and repeat suicidal behavior: a four-year prospective study. J Consult Clin Psychol. 2013;81(Issue):1137–1143. | KQ1 | 6
O’Connor RC, Smyth R, Williams JM. Intrapersonal positive future thinking predicts repeat suicide attempts in hospital-treated suicide attempters. J Consult Clin Psychol. 2015;83(Issue):169–176. | KQ1 | 6
O’Connor SS, Jobes DA, Lineberry TW, Michael Bostwick J. An investigation of emotional upset in suicide ideation. Arch Suicide Res. 2010;14(Issue):35–43. | KQ1 | 6
O’Donnell S, Meyer IH, Schwartz S. Increased risk of suicide attempts among Black and Latino lesbians, gay men, and bisexuals. Am J Public Health. 2011;101(Issue):1055–1059. | KQ1 | 4
Olfson M, Marcus SC. A case-control study of antidepressants and attempted suicide during early phase treatment of major depressive episodes. J Clin Psychiatry. 2008;69(Issue):425–432. | KQ1 | 4
Olie E, Picot MC, Guillaume S, Abbar M, Courtet P. Measurement of total serum cholesterol in the evaluation of suicidal risk. J Affect Disord. 2011;133(Issue):234–238. | KQ1 | 4
Omrani MD, Bushehri B, Bagheri M, et al. Role of IL-10-1082, IFN-gamma +874, and TNF-alpha-308 genes polymorphisms in suicidal behavior. Arch Suicide Res. 2009;13(Issue):330–339. | KQ1 | 2
Oquendo MA, Galfalvy HC, Currier D, et al. Treatment of suicide attempters with bipolar disorder: A randomized clinical trial comparing lithium and valproate in the prevention of suicidal behavior. Am J Psychiatry. 2011;168(Issue):1050–1056. | KQ2 | 4
Osman A, Gutierrez PM, Wong JL, Freedenthal S, Bagge CL, Smith KD. Development and Psychometric Evaluation of the Suicide Anger Expression Inventory-28. J Psychopathol Behav Assess. 2010;32(Issue):595–608. | KQ1 | 6
Ougrin D, Boege I, Stahl D, Banarsee R, Taylor E. Randomised controlled trial of therapeutic assessment versus usual assessment in adolescents with self-harm: 2-year follow-up. Arch Dis Child. 2013;98(Issue):772–776. | KQ2 | 3
Ougrin D, Zundel T, Ng A, Banarsee R, Bottle A, Taylor E. Trial of Therapeutic Assessment in London: randomised controlled trial of Therapeutic Assessment versus standard psychosocial assessment in adolescents presenting with self-harm. Arch Dis Child. 2011;96(Issue):148–153. | KQ2 | 3
Overholser JC, Braden A, Dieter L. Understanding suicide risk: identification of high-risk groups during high-risk times. J Clin Psychol. 2012;68(Issue):349–361. | KQ1 | 4
Owens C, Owen G, Lambert H, et al. Public involvement in suicide prevention: understanding and strengthening lay responses to distress. BMC Public Health. 2009;9(Issue):308. | KQ2 | 7
Pacchiarotti I, Valenti M, Colom F, et al. Differential outcome of bipolar patients receiving antidepressant monotherapy versus combination with an antimanic drug. J Affect Disord. 2011;129(Issue):321–326. | KQ2 | 2
Palmier-Claus JE, Taylor PJ, Gooding P, Dunn G, Lewis SW. Affective variability predicts suicidal ideation in individuals at ultra-high risk of developing psychosis: an experience sampling study. Br J Clin Psychol. 2012;51(Issue):72–83. | KQ1 | 4
Pan YJ, Chang WH, Lee MB, Chen CH, Liao SC, Caine ED. Effectiveness of a nationwide aftercare program for suicide attempters. Psychol Med. 2013;43(Issue):1447–1454. | KQ2 | 2
Pan YJ, Stewart R, Chang CK. Socioeconomic disadvantage, mental disorders and risk of 12-month suicide ideation and attempt in the National Comorbidity Survey Replication (NCS-R) in US. Soc Psychiatry Psychiatr Epidemiol. 2013;48(Issue):71–79. | KQ1 | 4
Panos PT, Jackson JW, Hasan O, Panos A. Meta-analysis and systematic review assessing the efficacy of Dialectical Behavior Therapy (DBT). Research on Social Work Practice. 2014;24(Issue):213–223. | KQ2 | 9
Patel AS, Harrison A, Bruce-Jones W. Evaluation of the risk assessment matrix: a mental health triage tool. Emerg Med J. 2009;26(Issue):11–14. | KQ1 | 6
Patorno E, Bohn RL, Wahl PM, et al. Anticonvulsant medications and the risk of suicide, attempted suicide, or violent death. JAMA. 2010;303(Issue):1401–1409. | KQ1 | 4
Payne SE, Hill JV, Johnson DE. The use of unit watch or command interest profile in the management of suicide and homicide risk: rationale and guidelines for the military mental health professional. Mil Med. 2008;173(Issue):25–35. | KQ2 | 7
Perron S, Burrows S, Fournier M, Perron P-A, Ouellet F. Installation of a bridge barrier as a suicide prevention strategy in Montreal, Quebec, Canada. Am J Public Health. 2013;103(Issue):1235–1239. | KQ2 | 4
Pfeiffer PN, Ganoczy D, Ilgen M, Zivin K, Valenstein M. Comorbid anxiety as a suicide risk factor among depressed veterans. Depress Anxiety. 2009;26(Issue):752–757. | KQ1 | 4
Pfeiffer PN, Kim HM, Ganoczy D, Zivin K, Valenstein M. Treatment-resistant depression and risk of suicide. Suicide Life Threat Behav. 2013;43(Issue):356–365. | KQ1 | 4
Pheister M, Kangas G, Thompson C, Lehrmann J, Berger B, Kemp J. Suicide prevention and postvention resources: what psychiatry residencies can learn from the Veteran’s Administration experience. Acad Psychiatry. 2014;38(Issue):600–604. | KQ2 | 7
Phelan JC, Sinkewicz M, Castille DM, Huz S, Muenzenmaier K, Link BG. Effectiveness and outcomes of assisted outpatient treatment in New York State. Psychiatr Serv. 2010;61(Issue):137–143. | KQ2 | 6
Pickles A, Aglan A, Collishaw S, Messer J, Rutter M, Maughan B. Predictors of suicidality across the life span: the Isle of Wight study. Psychol Med. 2010;40(Issue):1453–1466. | KQ1 | 4
Pigeon WR, Caine ED. Insomnia and the risk for suicide: Does sleep medicine have interventions that can make a difference? Sleep Med. 2010;11(Issue):816–817. | KQ2 | 8
Pintor L, Torres X, Navarro V, Martinez de Osaba MA, Matrai S, Gasto C. Prediction of relapse in melancholic depressive patients in a 2-year follow-up study with corticotropin releasing factor test. Prog Neuropsychopharmacol Biol Psychiatry. 2009;33(Issue):463–469. | KQ1 | 4
Pistorello J, Fruzzetti AE, Maclane C, Gallop R, Iverson KM. Dialectical behavior therapy (DBT) applied to college students: a randomized clinical trial. J Consult Clin Psychol. 2012;80(Issue):982–994. | KQ2 | 6
Plakun EM. A view from Riggs: treatment resistance and patient authority-XI. An alliance based intervention for suicide. J Am Acad Psychoanal Dyn Psychiatry. 2009;37(Issue):539–560. | KQ2 | 8
Pompili M, Baldessarini RJ, Tondo L, et al. Response to intravenous antidepressant treatment by suicidal vs. nonsuicidal depressed patients. J Affect Disord. 2010;122(Issue):154–158. | KQ2 | 2
Pompili M, Innamorati M, Mann JJ, et al. Periventricular white matter hyperintensities as predictors of suicide attempts in bipolar disorders and unipolar depression. Prog Neuropsychopharmacol Biol Psychiatry. 2008;32(Issue):1501–1507. | KQ1 | 2
Pompili M, Lester D, Innamorati M, et al. Suicide risk and exposure to mobbing. Work. 2008;31(Issue):237–243. | KQ1 | 2
Popovic D, Torrent C, Goikolea J, et al. Clinical implications of predominant polarity and the polarity index in bipolar disorder: A naturalistic study. Acta Psychiatr Scand. 2014;129(Issue):366–374. | KQ1 | 4
Posner K, Brown GK, Stanley B, et al. The Columbia-Suicide Severity Rating Scale: initial validity and internal consistency findings from three multisite studies with adolescents and adults. Am J Psychiatry. 2011;168(Issue):1266–1277. | KQ1 | 6
Pregelj P, Nedic G, Paska AV, et al. The association between brain-derived neurotrophic factor polymorphism (BDNF Val66Met) and suicide. J Affect Disord. 2011;128(Issue):287–290. | KQ1 | 2
Preuss UW, Wurst FM, Ridinger M, et al. Association of functional DBH genetic variants with alcohol dependence risk and related depression and suicide attempt phenotypes: results from a large multicenter association study. Drug Alcohol Depend. 2013;133(Issue):459–467. | KQ1 | 2
Price RB, Iosifescu DV, Murrough JW, et al. Effects of ketamine on explicit and implicit suicidal cognition: a randomized controlled trial in treatment-resistant depression. Depress Anxiety. 2014;31(Issue):335–343. | KQ2 | 6
Pukay-Martin ND, Pontoski KE, Maxwell MA, et al. The influence of depressive symptoms on suicidal ideation among U.S. Vietnam-era and Afghanistan/Iraq-era veterans with posttraumatic stress disorder. J Trauma Stress. 2012;25(Issue):578–582. | KQ1 | 6
Quevedo L, da Silva RA, Coelho F, et al. Risk of suicide and mixed episode in men in the postpartum period. J Affect Disord. 2011;132(Issue):243–246. | KQ1 | 2
Rahme E, Dasgupta K, Turecki G, Nedjar H, Galbaud du Fort G. Risks of suicide and poisoning among elderly patients prescribed selective serotonin reuptake inhibitors: a retrospective cohort study. J Clin Psychiatry. 2008;69(Issue):349–357. | KQ1 | 4
Raja M, Azzoni A. Are antidepressants warranted in the treatment of patients who present suicidal behavior? Hum Psychopharmacol. 2008;23(Issue):661–668. | KQ2 | 6
Rajalin M, Hirvikoski T, Jokinen J. Family history of suicide and exposure to interpersonal violence in childhood predict suicide in male suicide attempters. J Affect Disord. 2013;148(Issue):92–97. | KQ1 | 2
Randall JR, Colman I, Rowe BH. A systematic review of psychometric assessment of self-harm risk in the emergency department. J Affect Disord. 2011;134(Issue):348–355. | KQ1 | 9
Randall JR, Rowe BH, Colman I. Emergency department assessment of self-harm risk using psychometric questionnaires. Can J Psychiatry. 2012;57(Issue):21–28. | KQ1 | 6
Randall JR, Rowe BH, Dong KA, Nock MK, Colman I. Assessment of self-harm risk using implicit thoughts. Psychol Assess. 2013;25(Issue):714–721. | KQ1 | 6
Randall JR, Walld R, Finlayson G, Sareen J, Martens PJ, Bolton JM. Acute risk of suicide and suicide attempts associated with recent diagnosis of mental disorders: a population-based, propensity score-matched analysis. Can J Psychiatry. 2014;59(Issue):531–538. | KQ1 | 4
Razykov I, Ziegelstein RC, Whooley MA, Thombs BD. The PHQ-9 versus the PHQ-8--is item 9 useful for assessing suicide risk in coronary artery disease patients? Data from the Heart and Soul Study. J Psychosom Res. 2012;73(Issue):163–168. | KQ1 | 6
Reeves H, Batra S, May RS, Zhang R, Dahl DC, Li X. Efficacy of risperidone augmentation to antidepressants in the management of suicidality in major depressive disorder: A randomized, double-blind, placebo-controlled pilot study. J Clin Psychiatry. 2008;69(Issue):1228–1236. | KQ2 | 6
Reijas T, Ferrer E, Gonzalez A, Iglesias F. Evaluation of an intensive intervention program in suicidal behaviour. Actas Esp Psiquiatr. 2013;41(Issue):279–286. | KQ2 | 2
Ribeiro J, Franklin J, Fox K, et al. Self-injurious thoughts and behaviors as risk factors for future suicide ideation, attempts, and death: a meta-analysis of longitudinal studies. Psychol Med. 2015;2015 Sep 15 [Epub ahead of print](Issue):1–12. | KQ1 | 2
Ribeiro JD, Braithwaite SR, Pfaff JJ, Joiner TE. Examining a brief suicide screening tool in older adults engaging in risky alcohol use. Suicide Life Threat Behav. 2012;42(Issue):405–415. | KQ1 | 6
Ribeiro JD, Silva C, Joiner TE. Overarousal interacts with a sense of fearlessness about death to predict suicide risk in a sample of clinical outpatients. Psychiatry Res. 2014;218(Issue):106–112. | KQ1 | 4
Ribeiro JD, Yen S, Joiner T, Siegler IC. Capability for suicide interacts with states of heightened arousal to predict death by suicide beyond the effects of depression and hopelessness. J Affect Disord. 2015;188(Issue):53–59. | KQ1 | 6
Richard-Devantoy S, Jollant F, Kefi Z, et al. Deficit of cognitive inhibition in depressed elderly: a neurocognitive marker of suicidal risk. J Affect Disord. 2012;140(Issue):193–199. | KQ1 | 4
Richardson JD, St Cyr KC, McIntyre-Smith AM, Haslam D, Elhai JD, Sareen J. Examining the association between psychiatric illness and suicidal ideation in a sample of treatment-seeking Canadian peacekeeping and combat veterans with posttraumatic stress disorder PTSD. Can J Psychiatry. 2012;57(Issue):496–504. | KQ1 | 4
Rings JA, Alexander PA, Silvers VN, Gutierrez PM. Adapting the Safety Planning Intervention for use in a veterans psychiatric inpatient group setting. J Ment Health Couns. 2012;34(Issue):95–109. | KQ2 | 6
Roaldset JO, Linaker OM, Bjorkly S. Predictive validity of the MINI suicidal scale for self-harm in acute psychiatry: a prospective study of the first year after discharge. Arch Suicide Res. 2012;16(Issue):287–302. | KQ1 | 2
Robinson J, Cotton S, Conus P, Schimmelmann BG, McGorry P, Lambert M. Prevalence and predictors of suicide attempt in an incidence cohort of 661 young people with first-episode psychosis. Aust N Z J Psychiatry. 2009;43(Issue):149–157. | KQ1 | 3
Robinson J, Hetrick SE, Martin C. Preventing suicide in young people: systematic review. Aust N Z J Psychiatry. 2011;45(Issue):3–26. | KQ1 | 9
Robinson J, Rodrigues M, Fisher S, Bailey E, Herrman H. Social media and suicide prevention: Findings from a stakeholder survey. Shanghai Archives of Psychiatry. 2014;27(Issue):27–35. | KQ2 | 6
Rock DJ, Hallmayer JF. The seasonal risk for deliberate self-harm. Determined by place of birth, but occurrence determined by place of residence. Crisis. 2008;29(Issue):191–201. | KQ1 | 4
Rodriguez JR, Quinones-Maldonado R, Alvarado-Pomales A. Military suicide: factors that need to be taken into consideration to understand the phenomena. Bol Asoc Med P R. 2009;101(Issue):33–41. | KQ1 & KQ2 | 8
Rodriguez R, Molet J, Puerta P, Perez V, Puigdemont D, Gironell A. Deep brain stimulation for severe treatment-resistant depression. Stereotact Funct Neurosurg. 2013;91(Issue). | KQ2 | 2
Ronquillo L, Minassian A, Vilke GM, Wilson MP. Literature-based recommendations for suicide assessment in the emergency department: a review. J Emerg Med. 2012;43(Issue):836–842. | KQ1 | 9
Rossouw TI, Fonagy P. Mentalization-based treatment for self-harm in adolescents: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2012;51(Issue):1304–1313.e1303. | KQ2 | 3
Rossow I, Mehlum L, Gjertsen F, Moller B. Chain of care for patients with intentional self-harm: An effective strategy to reduce suicide rates? Suicide Life Threat Behav. 2009;39(Issue):614–622. | KQ2 | 2
Roux P, Villes V, Blanche J, et al. Buprenorphine in primary care: risk factors for treatment injection and implications for clinical management. Drug Alcohol Depend. 2008;97(Issue):105–113. | KQ1 | 2
Roy A, Carli V, Sarchiapone M. Resilience mitigates the suicide risk associated with childhood trauma. J Affect Disord. 2011;133(Issue):591–594. | KQ1 | 4
Roy A. Combination of family history of suicidal behavior and childhood trauma may represent correlate of increased suicide risk. J Affect Disord. 2011;130(Issue):205–208. | KQ1 | 4
Roy A. Risk factors for attempting suicide in heroin addicts. Suicide Life Threat Behav. 2010;40(Issue):416–420. | KQ1 | 6
Rudd MD, Berman AL, Joiner TE, Jr., et al. Warning signs for suicide: theory, research, and clinical applications. Suicide Life Threat Behav. 2006;36(Issue):255–262. | KQ1 | 6
Rusch N, Schiel S, Corrigan PW, et al. Predictors of dropout from inpatient dialectical behavior therapy among women with borderline personality disorder. J Behav Ther Exp Psychiatry. 2008;39(Issue):497–503. | KQ1 | 2
Russell G, Owens D. Psychosocial assessment following self-harm: repetition of nonfatal self-harm after assessment by psychiatrists or mental health nurses. Crisis. 2010;31(Issue):211–216. | KQ1 | 6
Ryan C, Huebner D, Diaz RM, Sanchez J. Family rejection as a predictor of negative health outcomes in white and Latino lesbian, gay, and bisexual young adults. Pediatrics. 2009;123(Issue):346–352. | KQ1 | 6
Ryb GE, Cooper CC, Dischinger PC, Kufera JA, Auman KM, Soderstrom CA. Suicides, homicides, and unintentional injury deaths after trauma center discharge: cocaine use as a risk factor. J Trauma. 2009;67(Issue):490–496; discussion 497. | KQ1 | 4
Sabodash V, Mendez MF, Fong S, Hsiao JJ. Suicidal behavior in dementia: a special risk in semantic dementia. Am J Alzheimers Dis Other Demen. 2013;28(Issue):592–599. | KQ1 | 3
Sadeh N, McNiel DE. Facets of anger, childhood sexual victimization, and gender as predictors of suicide attempts by psychiatric patients after hospital discharge. J Abnorm Psychol. 2013;122(Issue):879–890. | KQ1 | 4
Sahlem GL, Kalivas B, Fox JB, et al. Adjunctive triple chronotherapy (combined total sleep deprivation, sleep phase advance, and bright light therapy) rapidly improves mood and suicidality in suicidal depressed inpatients: An open label pilot study. J Psychiatr Res. 2014;59(Issue):101–107. | KQ2 | 6
Saman DM, Walsh S, Borowko A, Odoi A. Does place of residence affect risk of suicide? a spatial epidemiologic investigation in Kentucky from 1999 to 2008. BMC Public Health. 2012;12(Issue):108. | KQ1 | 4
Samandari G, Martin SL, Kupper LL, Schiro S, Norwood T, Avery M. Are pregnant and postpartum women: at increased risk for violent death? Suicide and homicide findings from North Carolina. Matern Child Health J. 2011;15(Issue):660–669. | KQ1 | 4
Sanmukhani J, Satodia V, Trivedi J, et al. Efficacy and safety of curcumin in major depressive disorder: A randomized controlled trial. Phytotherapy research : PTR. 2014;28(Issue):579–585. | KQ2 | 2
Sarchiapone M, Carli V, Roy A, et al. Association of polymorphism (Val66Met) of brain-derived neurotrophic factor with suicide attempts in depressed patients. Neuropsychobiology. 2008;57(Issue):139–145. | KQ1 | 2
Saulsberry A, Marko-Holguin M, Blomeke K, et al. Randomized clinical trial of a primary care internet-based intervention to prevent adolescent depression: One-year outcomes. J Can Acad Child Adolesc Psychiatry. 2013;22(Issue):106–117. | KQ2 | 3
Sauvaget A, Guitteny M, Bulteau S, et al. Consultation-liaison psychiatry interventions for the assessment of inpatients with suicidal behaviour: A prospective study in general hospital. J Psychosom Res. 2013;74(Issue):557–558. | KQ2 | 2
Schechter M, Lineberry TW. Self-harming behavior and suicidality: suicide risk assessment. Suicide Life Threat Behav. 2011;41(Issue):227–234. | KQ1 | 8
Schmidt NB, Capron DW, Raines AM, Allan NP. Randomized clinical trial evaluating the efficacy of a brief intervention targeting anxiety sensitivity cognitive concerns. J Consult Clin Psychol. 2015;82(Issue):1023–1033. | KQ2 | 6
Schneeweiss S, Patrick AR, Solomon DH, et al. Variation in the risk of suicide attempts and completed suicides by antidepressant agent in adults: a propensity score-adjusted analysis of 9 years’ data. Arch Gen Psychiatry. 2010;67(Issue):497–506. | KQ1 | 4
Schneider B, Grebner K, Schnabel A, Hampel H, Georgi K, Seidler A. Impact of employment status and work-related factors on risk of completed suicide. A case-control psychological autopsy study. Psychiatry Res. 2011;190(Issue):265–270. | KQ1 | 2
Schneider B, Schnabel A, Wetterling T, Bartusch B, Weber B, Georgi K. How do personality disorders modify suicide risk? J Pers Disord. 2008;22(Issue):233–245. | KQ1 | 4
Schneider B, Wetterling T, Georgi K, Bartusch B, Schnabel A, Blettner M. Smoking differently modifies suicide risk of affective disorders, substance use disorders, and social factors. J Affect Disord. 2009;112(Issue):165–173. | KQ1 | 2
Schoenbaum M, Kessler RC, Gilman SE, et al. Predictors of suicide and accident death in the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS): results from the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS). JAMA Psychiatry. 2014;71(Issue):493–503. | KQ1 | 4
Schwartz AJ. Rate, relative risk, and method of suicide by students at 4-year colleges and universities in the United States, 2004–2005 through 2008–2009. Suicide Life Threat Behav. 2011;41(Issue):353–371. | KQ1 | 4
Scott A, Doughty C, Kahi H. ‘Having those conversations’: The politics of risk in peer support practice. Health Sociology Review. 2011;20(Issue):187–201. | KQ2 | 4
Scott A, Guo B. For which strategies of suicide prevention is there evidence of effectiveness? Copenhagen, Denmark: World Health Organization, HEN synthesis report;2012. | KQ2 | 9
Seemuller F, Meier S, Obermeier M, et al. Three-year long-term outcome of 458 naturalistically treated inpatients with major depressive episode: Severe relapse rates and risk factors. Eur Arch Psychiatry Clin Neurosci. 2014;264(Issue):567–575. | KQ2 | 2
Selaman ZM, Chartrand HK, Bolton JM, Sareen J. Which symptoms of post-traumatic stress disorder are associated with suicide attempts? J Anxiety Disord. 2014;28(Issue):246–251. | KQ1 | 4
Serafini G, Pompili M, Innamorati M, et al. Affective temperamental profiles are associated with white matter hyperintensity and suicidal risk in patients with mood disorders. J Affect Disord. 2011;129(Issue):47–55. | KQ1 | 2
Serpa JG, Taylor SL, Tillisch K. Mindfulness-based stress reduction (MBSR) reduces anxiety, depression, and suicidal ideation in veterans. Med Care. 2014;52(Issue):S19–24. | KQ2 | 6
Shah A. Does improvement in the treatment of those who attempt suicide contribute to a reduction in elderly suicide rates in England? Int Psychogeriatr. 2009;21(Issue):768–773. | KQ2 | 4
Sheehan DV, Rozova A, Gossen ER, Gibertini M. The efficacy and tolerability of once-daily controlled-release trazodone for depressed mood, anxiety, insomnia, and suicidality in major depressive disorder. Psychopharmacol Bull. 2009;42(Issue):5–22. | KQ2 | 6
Shinozaki G, Romanowicz M, Passov V, Rundell J, Mrazek D, Kung S. State dependent gene-environment interaction: serotonin transporter gene-child abuse interaction associated with suicide attempt history among depressed psychiatric inpatients. J Affect Disord. 2013;147(Issue):373–378. | KQ1 | 4
Shrivastava A, Johnston M, Nelson C, Lester D. Predicting suicidality among psychiatric patients. Psychol Rep. 2011;109(Issue):367–368. | KQ1 | 6
Simmons M, Meador-Woodruff JH, Sodhi MS. Increased cortical expression of an RNA editing enzyme occurs in major depressive suicide victims. Neuroreport. 2010;21(Issue):993–997. | KQ1 | 4
Simon GE, Rutter CM, Peterson D, et al. Does response on the PHQ-9 Depression Questionnaire predict subsequent suicide attempt or suicide death? Psychiatr Serv. 2013;64(Issue):1195–1202. | KQ1 | 4
Singh AB, Bousman CA, Ng CH, Berk M. High impact child abuse may predict risk of elevated suicidality during antidepressant initiation. Aust N Z J Psychiatry. 2013;47(Issue):1191–1195. | KQ1 | 6
Slade K, Edelman R. Can theory predict the process of suicide on entry to prison? Predicting dynamic risk factors for suicide ideation in a high-risk prison population. Crisis. 2014;35(Issue):82–89. | KQ1 | 4
Slama F, Courtet P, Golmard JL, et al. Admixture analysis of age at first suicide attempt. J Psychiatr Res. 2009;43(Issue):895–900. | KQ1 | 2
Slee N, Spinhoven P, Garnefski N, Arensman E. Emotion regulation as mediator of treatment outcome in therapy for deliberate self-harm. Clin Psychol Psychother. 2008;15(Issue):205–216. | KQ2 | 2
Smith GW, Shevlin M, Murphy J, Houston JE. An assessment of the demographic and clinical correlates of the dimensions of alcohol use behaviour. Alcohol Alcohol. 2010;45(Issue):563–572. | KQ1 | 4
Sockalingam S, Flett H, Bergmans Y. A pilot study in suicide intervention training using a group intervention for patients with recurrent suicide attempts. Acad Psychiatry. 2010;34(Issue):132–135. | KQ1 | 7
Sokolowski M, Ben-Efraim YJ, Wasserman J, Wasserman D. Glutamatergic GRIN2B and polyaminergic ODC1 genes in suicide attempts: associations and gene-environment interactions with childhood/adolescent physical assault. Mol Psychiatry. 2013;18(Issue):985–992. | KQ1 | 2
Soloff PH, Chiappetta L. Prospective predictors of suicidal behavior in borderline personality disorder at 6-year follow-up. Am J Psychiatry. 2012;169(Issue):484–490. | KQ1 | 4
Soloff PH, Fabio A. Prospective predictors of suicide attempts in borderline personality disorder at one, two, and two-to-five year follow-up. J Pers Disord. 2008;22(Issue):123–134. | KQ1 | 4
Song JY, Yu HY, Kim SH, et al. Assessment of risk factors related to suicide attempts in patients with bipolar disorder. J Nerv Ment Dis. 2012;200(Issue):978–984. | KQ1 | 2
Sorenson SB, Vines KA. Mental Health and Firearms in Community-Based Surveys: Implications for Suicide Prevention. Eval Rev. 2008;32(Issue):239–256. | KQ2 | 4
Sparks DL, Hunsaker JC, 3rd, Amouyel P, et al. Angiotensin I-converting enzyme I/D polymorphism and suicidal behaviors. Am J Med Genet B Neuropsychiatr Genet. 2009;150B(Issue):290–294. | KQ1 | 4
Spiwak R, Pagura J, Bolton JM, et al. Childhood exposure to caregiver suicidal behavior and risk for adult suicide attempts: findings from a national survey. Arch Suicide Res. 2011;15(Issue):313–326. | KQ1 | 4
Spring B, Ferguson MJ. CALM technology-supported intervention: Synopsis of evidence for an emerging class of practice tool. Transl Behav Med. 2011;1(Issue):8–9. | KQ2 | 6
Stanford University, National Institute of Mental Health. A Sleep-Oriented Intervention for Suicidal Behaviors. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01770587. Accessed September 25, 2015. | KQ2 | 8
Stanford University, VA Palo Alto Health Care System. A Brief Behavioral Sleep Intervention for Depression Among Military Veterans. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01958541. Accessed September 25, 2015. | KQ2 | 8
Stanley B, Brown GK. Safety planning intervention: A brief intervention to mitigate suicide risk. Cogn Behav Pract. 2012;19(Issue):256–264. | KQ2 | 8
Stefansson J, Nordstrom P, Jokinen J. Suicide Intent Scale in the prediction of suicide. J Affect Disord. 2012;136(Issue):167–171. | KQ1 | 2
Stevens D, Wilcox HC, MacKinnon DF, et al. Posttraumatic stress disorder increases risk for suicide attempt in adults with recurrent major depression. Depress Anxiety. 2013;30(Issue):940–946. | KQ1 | 4
Stone M, Laughren T, Jones M, et al. Risk of suicidality in clinical trials of antidepressants in adults: Analysis of proprietary data submitted to US Food and Drug Administration. BMJ. 2009;339(Issue). | KQ1 | 4
Strauss J, McGregor S, Freeman N, et al. Association study of early-immediate genes in childhood-onset mood disorders and suicide attempt. Psychiatry Res. 2012;197(Issue):49–54. | KQ1 | 4
Strom TQ, Leskela J, James LM, et al. An exploratory examination of risk-taking behavior and PTSD symptom severity in a veteran sample. Mil Med. 2012;177(Issue):390–396. | KQ1 | 6
Sublette ME, Galfalvy HC, Fuchs D, et al. Plasma kynurenine levels are elevated in suicide attempters with major depressive disorder. Brain Behav Immun. 2011;25(Issue):1272–1278. | KQ1 | 4
Sunnqvist C, Westrin A, Traskman-Bendz L. Suicide attempters: biological stressmarkers and adverse life events. Eur Arch Psychiatry Clin Neurosci. 2008;258(Issue):456–462. | KQ1 | 2
System VECHC. Clinician Access to Soldier Suicide Information (CASSI). ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01502865. Accessed September 25, 2015. | KQ2 | 4
Szumilas M, Kutcher S. Post-suicide intervention programs: a systematic review. Can J Public Health. 2011;102(Issue):18–29. | KQ2 | 9
Tarescavage AM, Windover A, Ben-Porath YS, et al. Use of the MMPI-2-RF Suicidal/Death Ideation and Substance Abuse scales in screening bariatric surgery candidates. Psychol Assess. 2013;25(Issue):1384–1389. | KQ1 | 4
Tarrier N, Taylor K, Gooding P. Cognitive-behavioral interventions to reduce suicide behavior: a systematic review and meta-analysis. Behav Modif. 2008;32(Issue):77–108. | KQ2 | 9
Taylor LM, Oldershaw A, Richards C, Davidson K, Schmidt U, Simic M. Development and pilot evaluation of a manualized cognitive-behavioural treatment package for adolescent self-harm. Behav Cogn Psychother. 2011;39(Issue):619–625. | KQ2 | 3
Taylor-Rodgers E, Batterham PJ. Evaluation of an online psychoeducation intervention to promote mental health help seeking attitudes and intentions among young adults: Randomised controlled trial. J Affect Disord. 2014;168(Issue):65–71. | KQ2 | 6
Thase M, Edwards J, Chen D, Ruth A. The efficacy of vilazodone on anxiety symptoms in patients with major depressive disorder: A post hoc analysis of two randomized controlled trials. Neuropsychopharmacology. 2012;38(Issue). | KQ2 | 6
The Catholic University of America, University of Washington, Department of Veterans Affairs. Operation Worth Living Project With Suicidal Soldiers at Ft. Stewart (OWL). ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01300169. Accessed September 25, 2015. | KQ2 | 8^†^
Titelman D, Nilsson A, Svensson B, Karlsson H, Bruchfeld S. Suicide-nearness assessed with PORT, the Percept-genetic Object-Relation Test: A replication and a reliability study. Bull Menninger Clin. 2011;75(Issue):295–314. | KQ1 | 4
Tohen M, Brunner E, Osuntokun O, Landry J, Schroer R, Thase M. Longer-term efficacy and safety of olanzapine and fluoxetine combination versus fluoxetine monotherapy following successful combination therapy of treatment-resistant depression. Neuropsychopharmacology. 2012;38(Issue). | KQ2 | 4
Tondo L, Baldessarini RJ. Long-term lithium treatment in the prevention of suicidal behavior in bipolar disorder patients. Epidemiol Psychiatr Sci. 2009;18(Issue):179–183. | KQ2 | 8
Tonstad S, Davies S, Flammer M, Russ C, Hughes J. Psychiatric adverse events in randomized, double-blind, placebo-controlled clinical trials of varenicline: a pooled analysis. Drug Saf. 2010;33(Issue):289–301. | KQ2 | 4
Torchalla I, Strehlau V, Li K, Schuetz C, Krausz M. The association between childhood maltreatment subtypes and current suicide risk among homeless men and women. Child Maltreat. 2012;17(Issue):132–143. | KQ1 | 4
Toro K, Dunay G, Rona K, Klausz G, Feher S. Alcohol-related mortality risk in natural and non-natural death cases. J Forensic Sci. 2009;54(Issue):1429–1432. | KQ1 | 2
Trivedi MH, Wisniewski SR, Morris DW, et al. Concise Associated Symptoms Tracking scale: a brief self-report and clinician rating of symptoms associated with suicidality. J Clin Psychiatry. 2011;72(Issue):765–774. | KQ1 | 4
Tsai SJ, Hong CJ, Liou YJ. Recent molecular genetic studies and methodological issues in suicide research. Prog Neuropsychopharmacol Biol Psychiatry. 2011;35(Issue):809–817. | KQ1 | 4
Turecki G, Ernst C, Jollant F, Labonte B, Mechawar N. The neurodevelopmental origins of suicidal behavior. Trends Neurosci. 2012;35(Issue):14–23. | KQ1 | 4
Tzang RF, Hong CJ, Liou YJ, Yu YW, Chen TJ, Tsai SJ. Association study of p11 gene with major depressive disorder, suicidal behaviors and treatment response. Neurosci Lett. 2008;447(Issue):92–95. | KQ1 | 2
Uebelacker LA, German NM, Gaudiano BA, Miller IW. Patient health questionnaire depression scale as a suicide screening instrument in depressed primary care patients: a cross-sectional study. Prim Care Companion CNS Disord. 2011;13(Issue). | KQ1 | 6
United States Naval Medical Center-San Diego. A Study to Decrease Suicidal Thinking Using Ketamine. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02418702. Accessed September 25, 2015. | KQ2 | 8
University Hospital of Brest, Technopôle Brest-Iroise: Lanestel Sarl. Short Message System (SMS) Monitoring Intended for the Suicidal Patients. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02106949. Accessed September 25, 2015. | KQ2 | 2
University Hospital of Lille. Effectiveness of a Case Management Algorithm: ALGOS After a Suicide Attempt. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01123174. Accessed September 25, 2015. | KQ2 | 2
University of Alabama at Birmingham, National Institute of Mental Health. miRNAs, Suicide, and Ketamine - Plasma Exosomal microRNAs as Novel Biomarkers for Suicidality and Treatment Outcome. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02418195. Accessed September 25, 2015. | KQ2 | 8
University of Alabama at Birmingham. Treatment of Suicidal Ideation With Intravenous Ketamine Infusion. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01887990. Accessed September 25, 2015. | KQ2 | 8
University of Cincinnati. Emergency Ketamine Treatment of Suicidal Ideation. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02183272. Accessed September 25, 2015. | KQ2 | 8
University of Manitoba, American Foundation for Suicide Prevention. Evaluation of a Gatekeeper Training Program. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01252927. Accessed September 25, 2015. | KQ2 | 8
University of Manitoba, Canadian Institutes of Health Research. Circle of Life. Improving Capacity of Swampy Cree Community Members to Recognize People at Risk for Suicide. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01287416. Accessed September 25, 2015. | KQ2 | 3
University of Manitoba, Manitoba Health, First Nations and Inuit Health. The Safety and Effectiveness of Gatekeeper Training in First Nations Communities. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT02118116. Accessed September 25, 2015. | KQ2 | 3
University of Massachusetts at Worcester, National Institute of Mental Health. Emergency Department Safety Assessment and Follow-up Evaluation 2 (ED-SAFE-2). ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02453243. Accessed September 25, 2015. | KQ2 | 8
University of Massachusetts W, National Institute of Mental H. Emergency Department Safety Assessment and Follow-up Evaluation (ED-SAFE). ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01150994. Accessed September 25, 2015. | KQ1 & KQ2 | 8
University of Michigan, National Institutes of Health, Pfeiffer P. Peer Mentorship to Reduce Suicide Risk Following Psychiatric Hospitalization (PREVAIL Study). ClinicalTrials.gov. 2015; NCT02365116. https://ClinicalTrials.gov/show/NCT02365116. Accessed September 25, 2015. | KQ2 | 8
University of Michigan, U. S. Army Medical Research and Materiel Command, Department of Defense, Department of Veterans Affairs. Intervening to Reduce Suicide Risk in Veterans With Substance Use Disorders. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02439762. Accessed September 25, 2015. | KQ2 | 8^†^
University of Nevada at Reno, The Catholic University of America, National Institute of Mental Health. Developing Adaptive Interventions for Suicidal College Students Seeking Treatment - SMART. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02442869. Accessed September 25, 2015. | KQ2 | 8
University of Pennsylvania, National Institute of Mental Health, Beck AT, Brown GK. Cognitive Therapy for Suicidal Older Men in Primary Care Settings. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT00149773. Accessed September 25, 2015. | KQ2 | 8
University of Pennsylvania, National Institute of Mental Health. Cognitive Therapy for Suicidal Older Men. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01535482. Accessed September 25, 2015. | KQ2 | 8
University of Rochester, National Institute of Mental Health. Social Connections and Late Life Suicide. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02188485. Accessed September 25, 2015. | KQ2 | 8
University of Utah, The University of Texas Health Science Center at San Antonio. Brief Interventions for Short-Term Suicide Risk Reduction in Military Populations. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02042131. Accessed September 25, 2015. | KQ2 | 8^†^
University of Washington, Military Suicide Research Consortium, Department of Veterans Affairs, Department of Defense. Military Continuity Project. ClinicalTrials.gov. 2013; https://ClinicalTrials.gov/show/NCT01829620. Accessed September 25, 2015. | KQ2 | 8^†^
University of Washington, National Institute of Mental Health. Treating PTSD in Patients With Borderline Personality Disorder. ClinicalTrials.gov. 2013; https://ClinicalTrials.gov/show/NCT01081314. Accessed September 25, 2015. | KQ2 | 8
University of Washington. A Policy Relevant US Trauma Care System Pragmatic Trial for PTSD and Comorbidity Pilot. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02335125. Accessed September 25, 2015. | KQ2 | 4
University of Washington. Brief Skills Training Intervention for Suicidal Individuals. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT02236325. Accessed September 25, 2015. | KQ2 | 8
University of Washington. Improving Care Provided to Patients Treated in a Level 1 Trauma Center Post-suicide Attempt. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01355848. Accessed September 25, 2015. | KQ2 | 8
VA Connecticut Healthcare System, Department of Veterans Affairs. Dialectical Behavior Therapy Skills Group Pilot Evaluation. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02499406. Accessed September 25, 2015. | KQ2 | 8
VA Eastern Colorado Health Care System, Department of Defense, Gutierrez P. Blister Packaging Medication to Increase Treatment Adherence and Clinical Response. ClinicalTrials.gov. 2015; NCT01118208. https://ClinicalTrials.gov/show/NCT01118208. Accessed September 25, 2015. | KQ2 | 8^†^
VA Eastern Colorado Health Care System, Department of Veterans Affairs, Department of Defense, Columbia University, University of Pennsylvania, Uniformed Services University of the Health Sciences. A Brief Intervention to Reduce Suicide Risk in Military Service Members and Veterans-Study 1. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01334541. Accessed September 25, 2015. | KQ2 | 8^†^
VA Eastern Colorado Health Care System, University of Colorado at Denver, Portland State University, University of Missouri at Kansas City. Operation Enduring Freedom/Operation Iraqi Freedom Veterans’ Experiences of Habituation to Pain, Perceived Burdensomeness, and Failed Belongingness. ClinicalTrials.gov. 2011; https://ClinicalTrials.gov/show/NCT01334385. Accessed September 25, 2015. | KQ1 | 4
VA Eastern Colorado Health Care System, University of Colorado at Denver. Prolonged Grief and Suicide Among Veterans. ClinicalTrials.gov. 2014; https://ClinicalTrials.gov/show/NCT01247025. Accessed September 25, 2015. | KQ1 | 4
VA Eastern Colorado Health Care System. An Exploration of the Relationship Between Chronic Pain and Suicide Attempt Among Veterans. ClinicalTrials.gov. 2012; https://ClinicalTrials.gov/show/NCT01502436. Accessed September 25, 2015. | KQ1 | 4
VA Eastern Colorado Health Care System. Experiential Avoidance in Combat Veterans With and Without Posttraumatic Stress Disorder. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT01652430. Accessed September 25, 2015. | KQ1 | 4
VA Eastern Colorado Health Care System. Personal Values, Interpersonal Needs, and Suicidal Ideation in a Veteran Population. ClinicalTrials.gov. 2011; https://ClinicalTrials.gov/show/NCT01118169. Accessed September 25, 2015. | KQ1 | 4
Vaiva G, Vaiva G, Ducrocq F, et al. Effect of telephone contact on further suicide attempts in patients discharged from an emergency department: randomised controlled study. BMJ. 2006;332(Issue):1241–1245. | KQ2 | 2
Valenstein M, Eisenberg D, McCarthy JF, et al. Service implications of providing intensive monitoring during high-risk periods for suicide among VA patients with depression. Psychiatr Serv. 2009;60(Issue):439–444. | KQ2 | 6
Valuck RJ, Orton HD, Libby AM. Antidepressant discontinuation and risk of suicide attempt: a retrospective, nested case-control study. J Clin Psychiatry. 2009;70(Issue):1069–1077. | KQ1 | 4
van Beek W, Kerkhof A, Beekman A. Future oriented group training for suicidal patients: a randomized clinical trial. BMC Psychiatry. 2009;9(Issue):65. | KQ2 | 2
van der Feltz-Cornelis CM, Sarchiapone M, Postuvan V, et al. Best practice elements of multilevel suicide prevention strategies: a review of systematic reviews. Crisis. 2011;32(Issue):319–333. | KQ2 | 9
van Spijker BAJ, Calear AL, Batterham PJ, et al. Reducing suicidal thoughts in the Australian general population through web-based self-help: Study protocol for a randomized controlled trial. Trials. 2015;16(Issue). | KQ2 | 8
Vang FJ, Lindstrom M, Sunnqvist C, Bah-Rosman J, Johanson A, Traskman-Bendz L. Life-time adversities, reported thirteen years after a suicide attempt: relationship to recovery, 5HTTLPR genotype, and past and present morbidity. Arch Suicide Res. 2009;13(Issue):214–229. | KQ1 | 2
Vriniotis M, Barber C, Frank E, Demicco R. A suicide prevention campaign for firearm dealers in new hampshire. Suicide Life Threat Behav. 2015;45(Issue):157–163. | KQ2 | 6
Wachtel S, Vocks S, Edel MA, Nyhuis P, Willutzki U, Teismann T. Validation and psychometric properties of the German Capability for Suicide Questionnaire. Compr Psychiatry. 2014;55(Issue):1292–1302. | KQ1 | 2
Waern M, Sjostrom N, Marlow T, Hetta J. Does the Suicide Assessment Scale predict risk of repetition? A prospective study of suicide attempters at a hospital emergency department. Eur Psychiatry. 2010;25(Issue):421–426. | KQ1 | 2
Wagner G, Koch K, Schachtzabel C, Schultz CC, Sauer H, Schlosser RG. Structural brain alterations in patients with major depressive disorder and high risk for suicide: evidence for a distinct neurobiological entity? Neuroimage. 2011;54(Issue):1607–1614. | KQ1 | 2
Wagner G, Schultz CC, Koch K, Schachtzabel C, Sauer H, Schlosser RG. Prefrontal cortical thickness in depressed patients with high-risk for suicidal behavior. J Psychiatr Res. 2012;46(Issue):1449–1455. | KQ1 | 2
Wang L-J, Wu Y-W, Chen C-K. Is case management effective for long-lasting suicide prevention? A community cohort study in Northern Taiwan. Crisis. 2015;36(Issue):194–201. | KQ2 | 2
Ward-Ciesielski EF. An open pilot feasibility study of a brief dialectical behavior therapy skills-based intervention for suicidal individuals. Suicide Life Threat Behav. 2013;43(Issue):324–335. | KQ2 | 6
Wasserman D, Sokolowski M, Rozanov V, Wasserman J. The CRHR1 gene: a marker for suicidality in depressed males exposed to low stress. Genes Brain Behav. 2008;7(Issue):14–19. | KQ1 | 2
Wasserman D, Terenius L, Wasserman J, Sokolowski M. The 2009 Nobel conference on the role of genetics in promoting suicide prevention and the mental health of the population. Mol Psychiatry. 2010;15(Issue):12–17. | KQ2 | 8
Wells TS, Horton JL, LeardMann CA, Jacobson IG, Boyko EJ. A comparison of the PRIME-MD PHQ-9 and PHQ-8 in a large military prospective study, the Millennium Cohort Study. J Affect Disord. 2013;148(Issue):77–83. | KQ1 | 4
Western Kentucky University, Vanderbilt University. Pilot Study of a Brief Intervention for Medically Hospitalized Suicide Attempt Survivors. ClinicalTrials.gov. 2015; https://ClinicalTrials.gov/show/NCT02414763. Accessed September 25, 2015. | KQ2 | 8
White R, Barber C, Azrael D, Mukamal KJ, Miller M. History of military service and the risk of suicidal ideation: findings from the 2008 national survey on drug use and health. Suicide Life Threat Behav. 2011;41(Issue):554–561. | KQ1 | 4
Williams AD, Andrews G. The effectiveness of internet cognitive behavioural therapy (iCBT) for depression in primary care: A quality assurance study. PLoS One. 2013;8(Issue). | KQ2 | 6
Willour VL, Seifuddin F, Mahon PB, et al. A genome-wide association study of attempted suicide. Mol Psychiatry. 2012;17(Issue):433–444. | KQ1 | 4
Winter D, Bradshaw S, Bunn F, Wellsted D. A systematic review of the literature on counselling and psychotherapy for the prevention of suicide: 2. Qualitative studies. Counselling and Psychotherapy Research. 2014;14(Issue):64–79. | KQ2 | 6
Winter D, Bradshaw S, Bunn F, Wellsted D. A systematic review of the literature on counselling and psychotherapy for the prevention of suicide: 1. Quantitative outcome and process studies. Counselling and Psychotherapy Research. 2013;13(Issue):164–183. | KQ2 | 9
Witte TK, Gould MS, Munfakh JL, Kleinman M, Joiner TE, Jr., Kalafat J. Assessing suicide risk among callers to crisis hotlines: a confirmatory factor analysis. J Clin Psychol. 2010;66(Issue):941–964. | KQ1 | 4
Witte TK, Timmons KA, Fink E, Smith AR, Joiner TE. Do major depressive disorder and dysthymic disorder confer differential risk for suicide? J Affect Disord. 2009;115(Issue):69–78. | KQ1 | 4
Wolk CB, Kendall PC, Beidas RS. Cognitive-behavioral therapy for child anxiety confers long-term protection from suicidality. J Am Acad Child Adolesc Psychiatry. 2015;54(Issue):175–179. | KQ2 | 4
Woodhead C, Rona RJ, Iversen A, et al. Mental health and health service use among post-national service veterans: results from the 2007 Adult Psychiatric Morbidity Survey of England. Psychol Med. 2011;41(Issue):363–372. | KQ1 | 4
Woolley SB, Fredman L, Goethe JW, Lincoln AK, Heeren T. Headache complaints and the risk of suicidal thoughts or behaviors. J Nerv Ment Dis. 2008;196(Issue):822–828. | KQ1 | 4
Wray M, Gurvey J, Miller M, Kawachi I. Estimating visitor suicide risk in destination cities: A reply to Zarkowski and Nguyen. Soc Sci Med. 2012;74(Issue):1474–1476. | KQ1 | 4
Wray M, Miller M, Gurvey J, Carroll J, Kawachi I. Leaving Las Vegas: Exposure to Las Vegas and risk of suicide. Soc Sci Med. 2008;67(Issue):1882–1888. | KQ1 | 4
Wright KM, Adler AB, Bliese PD, Eckford RD. Structured clinical interview guide for postdeployment psychological screening programs. Mil Med. 2008;173(Issue):411–421. | KQ1 | 6
Wyder M, Ward P, De Leo D. Separation as a suicide risk factor. J Affect Disord. 2009;116(Issue):208–213. | KQ1 | 4
Yaldizli O, Kuhl HC, Graf M, Wiesbeck GA, Wurst FM. Risk factors for suicide attempts in patients with alcohol dependence or abuse and a history of depressive symptoms: a subgroup analysis from the WHO/ISBRA study. Drug Alcohol Rev. 2010;29(Issue):64–74. | KQ1 | 2
Yaseen Z, Katz C, Johnson MS, Eisenberg D, Cohen LJ, Galynker, II. Construct development: The Suicide Trigger Scale (STS-2), a measure of a hypothesized suicide trigger state. BMC Psychiatry. 2010;10(Issue):110. | KQ1 | 6
Yen CF, Chen CS, Yen JY, Ko CH. The predictive effect of insight on adverse clinical outcomes in bipolar I disorder: a two-year prospective study. J Affect Disord. 2008;108(Issue):121–127. | KQ1 | 2
Yen CF, Lee Y, Tang TC, Yen JY, Ko CH, Chen CC. Predictive value of self-stigma, insight, and perceived adverse effects of medication for the clinical outcomes in patients with depressive disorders. J Nerv Ment Dis. 2009;197(Issue):172–177. | KQ1 | 2
Yen S, Shea MT, Sanislow CA, et al. Personality traits as prospective predictors of suicide attempts. Acta Psychiatr Scand. 2009;120(Issue):222–229. | KQ1 | 7
Yip P, Pitt D, Wang Y, et al. Assessing the impact of suicide exclusion periods on life insurance. Crisis. 2010;31(Issue):217–223. | KQ1 | 4
York J, Lamis DA, Friedman L, et al. A Systematic Review Process to Evaluate Suicide Prevention Programs: A Sample Case of Community-Based Programs. J Community Psychol. 2013;41(Issue):35–51. | KQ2 | 3
York JA, Lamis DA, Pope CA, Egede LE. Veteran-specific suicide prevention. Psychiatr Q. 2013;84(Issue):219–238. | KQ2 | 8
Yurgelun-Todd D. Using Brain Imaging to Study Suicide Risk. Military Suicide Research Consortium. https://msrc.fsu.edu/funded-research/using-brain-imaging-study-suicide-risk. Accessed September 25, 2015. | KQ1 | 4
Yur’yev A, Värnik A, Värnik P, Sisask M, Leppik L. Role of social welfare in European suicide prevention. Int J Soc Welfare. 2012;21(Issue):26–33. | KQ2 | 2
Zai CC, Manchia M, De Luca V, et al. The brain-derived neurotrophic factor gene in suicidal behaviour: a meta-analysis. Int J Neuropsychopharmacol. 2012;15(Issue):1037–1042. | KQ1 | 4
Zalsman G, Huang YY, Oquendo MA, et al. No association of COMT Val158Met polymorphism with suicidal behavior or CSF monoamine metabolites in mood disorders. Arch Suicide Res. 2008;12(Issue):327–335. | KQ1 | 4
Zhang J, Lu J, Zhao S, et al. Developing the Psychological Strain Scales (PSS): Reliability, Validity, and Preliminary Hypothesis Tests. Soc Indic Res. 2014;115(Issue):337–361. | KQ1 | 2
Zhang L, Su TP, Choi K, et al. P11 (S100A10) as a potential biomarker of psychiatric patients at risk of suicide. J Psychiatr Res. 2011;45(Issue):435–441. | KQ1 | 2
Zhang Y, Zhang C, Yuan G, et al. Effect of tryptophan hydroxylase-2 rs7305115 SNP on suicide attempts risk in major depression. Behav Brain Funct. 2010;6(Issue):49. | KQ1 | 2
Zisook S, Lesser IM, Lebowitz B, et al. Effect of antidepressant medication treatment on suicidal ideation and behavior in a randomized trial: An exploratory report form the combining medications to enhance depression outcomes study. J Clin Psychiatry. 2011;72(Issue):1322–1332. | KQ2 | 4

* Not included as a study in the systematic review because study results are not yet available, but listed in the table of Ongoing Studies of Methods to Identify Suicide Risk (Table 10).

† Not included as a study in the systematic review because study results are not yet available, but listed in the table of Ongoing Studies of Healthcare Service Interventions for Suicide Prevention (Table 11).