# STUDY SELECTION

## Inclusion Criteria

Category | Include | Exclude
Population | Veterans; military personnel; non-Veteran/military individuals age ≥18 who are demographically similar from US, UK, Canada, New Zealand, or Australia. | Individuals dissimilar to the included population; patients with other serious psychiatric or medical co-morbidities (eg, cancer).
Intervention | Population-directed healthcare services (eg, hotlines, outreach programs); individual-directed healthcare services (eg, case management, follow-up); services that are clinically relevant to medical practice in the US. | Interventions other than those specifically described in the inclusion criteria, including: interventions that primarily treat co-existing conditions, including pharmacotherapy.
Comparator | Intervention versus non-intervention, usual care, or other intervention. | Comparison groups using interventions other than those specifically described in the inclusion criteria.
Outcomes | Suicidal self-directed violence including suicide attempt and suicide; suicide-specific mortality. Additional secondary outcomes will be collected as available from studies designed primarily to capture suicidal self-directed violence. For KQ2, studies need to report a measure of diagnostic accuracy. | Self-directed violence ideation and undetermined or non-suicidal self-directed violence; other outcomes not listed as included.
Timing | All included. | No limitations.
Setting | For risk assessment and intervention studies: Veteran or military inpatient or outpatient setting; or comparable non-Veteran/military setting. | Settings not applicable to US Veteran or military populations.
Study Design | KQ1: Studies reporting diagnostic accuracy for methods to identify at-risk individuals using best evidence approach. Methods include risk assessment instruments and checklists of clinical symptoms and warning signs, for example; comparisons between various settings and modes of delivery, targeting specific populations, and other approaches. KQ2: Effectiveness: randomized controlled trials (RCTs); observational studies with comparison groups, systematic reviews with these study designs. Adverse effects: RCTs, observational studies, systematic reviews, meta-analyses, and modeling studies; others considered. KQ3: New studies of risk assessment and interventions specific to Veterans/military personnel. | Case reports.
Language | English-language abstracts (includes English-language abstracts of non-English language papers) and papers. | Non English-language papers.
Data Sources | Ovid MEDLINE, PubMed, PsycINFO, SocINDEX, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, grey literature sources. | Sources not listed as included.
Search Dates | Varies by key question; for questions addressed by prior systematic reviews, searches will include dates since the prior searches. | Studies published outside of the specified search dates.

## Study Selection Process

### Importing Citations into EndNote Library

Search results were imported into the EndNote library and search characteristics (database name, date of search) were entered into Custom 1.

### Title/Abstract Review

All titles and abstracts were reviewed to eliminate obviously irrelevant publications. A single reviewer provided decision codes that were recorded in Custom 3 of the EndNote library.

#### Decision codes:

- R = Retrieve for full-text review
- E = Exclude (not eligible for inclusion)
- B = Retrieve for Background only (not eligible for inclusion)

### Full-text Review

Two reviewers independently assessed the eligibility of references coded for full-text review. Each reviewer recorded a decision code. All disagreements about inclusion were resolved using a consensus process and/or review by the Principal Investigator (HDN).

#### Exclusion Codes:

- 1 = Non-English language
- 2 = Ineligible country (ie, any country other than the US, UK, Canada, New Zealand, Australia)
- 3 = Ineligible population or setting (eg, children or adolescents, patients with serious comorbidities such as cancer, nursing home populations, institutionalized populations)
- 4 = Study does not involve diagnostic accuracy of suicide risk assessment (KQ 1) or a healthcare service intervention to prevent suicide (KQ2)
- 5 = Study does not have a comparison group
- 6 = Ineligible outcome
- 7 = Ineligible study design (eg, case reports, case series)
- 8 = Ineligible publication type (eg, letter, editorial, publication available only as abstract, protocol without results, non-systematic review or regulatory agency analysis)
- 9 = Ineligible systematic review (due to scope, inclusion criteria, or limitations in quality)