# SEARCH STRATEGIES

## ELECTRONIC DATABASE SEARCHES

### Databases Searched

- MEDLINE via PubMed
- PsycINFO via OVID
- Cochrane Central Register of Controlled Trials (CCRCT) via OVID
- SocINDEX* via EBSCOHost

### Search Strategies

All searches were updated September 11, 2015.

MEDLINE via PubMed

Searched March 3, 2015^*^

Concept | Search Terms
Suicide | ((“Suicide”[Mesh]) OR “Suicidal Ideation”[Mesh]) OR “Suicide, Attempted”[Mesh]
Suicide | OR (suicide[Title/Abstract] OR suicidal[Title/Abstract] OR suicidality[Title/Abstract] OR parasuicide[Title/Abstract] OR self-harm[Title/Abstract] OR “self-directed violence”[Title/Abstract] OR parasuicidal[Title/Abstract]) NOT “non-suicidal self injury”[Title/Abstract]
Prevention | “prevention and control” [Subheading] OR “Tertiary Prevention”[Mesh] OR “Secondary Prevention”[Mesh] OR “Primary Prevention”[Mesh]
Prevention | OR (prevent*[Title/Abstract] OR control[Title/Abstract])
Risk Prediction | (((((“Risk”[Mesh]) OR “Risk Reduction Behavior”[Mesh]) OR “Risk Assessment”[Mesh]) OR “Risk Factors”[Mesh]) OR “Mass Screening”[Mesh]) OR “Validation Studies” [Publication Type]
Risk Prediction | OR (risk[Title] OR screening[Title] OR screen[Title] OR assessment[Title] OR assessments[Title] OR questionnaire[Title] OR questionnaires[Title] OR instrument[Title] OR instruments[Title] OR tool[Title] OR tools[Title] OR scale[Title] OR scales[Title] OR measure[Title] OR measures[Title] OR correlate*[Title] OR “risk-stratification”[Title] OR predict[Title] OR predicts[Title] OR predictor[Title] OR predictors[Title]) OR (((((((ReACT Self Harm Rule[Title/Abstract]) OR Suicidal Ideation Attributes Scale[Title/Abstract]) OR Suicide Trigger Scale[Title/Abstract]) OR Cultural Assessment of Risk for suicide[Title/Abstract]) OR Affective Intensity Rating Scale[Title/Abstract]) OR Columbia Suicide Severity Rating Scale[Title/Abstract]) OR Edinburgh Risk of Repetition Scale[Title/Abstract]) OR Manchester Self Harm tool[Title/Abstract]
Limits: Humans Adults English only Last 5 years Not letters, editorials | NOT (((“Letter” [Publication Type]) OR “Editorial” [Publication Type]) OR “Comment” [Publication Type]) Filters: published from January 2008 to Present; Humans; English; Adult: 19+ years N=3411 After de-duplication N=2913

* Update search on September 11, 2015; 4 additional records retrieved.

PsychINFO via OVID

Searched March 3, 2015^*^

Database: PsycINFO <1806 to February Week 4 2015>
Search Strategy:
1. suicide/ or attempted suicide/ or suicidal ideation/ (29009); 2. (suicide or suicidal or suicidality or parasuicide or self-harm or “self-directed violence” or parasuicidal).mp. (49986); 3. 1 or 2 (49986); 4. exp Suicide Prevention/ or prevention.mp. or exp Suicide Prevention Centers/ (98208); 5. exp Risk Assessment/ or risk.mp. or exp Risk Factors/ (249298); 6. (risk or screening or screen or assessment or assessments or questionnaire or questionnaires or instrument or instruments or tool or tools or scale or scales or measure or measures or correlate* or “risk stratification” or predict or predicts or predictor or predictors).mp. (1380001); 7. ReACT Self Harm Rule.mp. (3); 8. Suicidal Ideation Attributes Scale.mp. (2); 9. Suicide Trigger Scale.mp. (4); 10. Cultural Assessment of Risk for suicide.mp. (5); 11. Affective Intensity Rating Scale.mp. (2); 12. Columbia Suicide Severity Rating Scale.mp. (183); 13. Edinburgh Risk of Repetition Scale.mp. (2); 14. Manchester Self Harm tool.mp. (0); 15. 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 (1380001); 16. 4 or 15 (1420668); 17. 3 and 16 (30393); 18. limit 17 to (peer reviewed journal and human and english language and treatment & prevention and adulthood <18+ years> and from January 2008 to Present) (1445) after deduplication N= 946

* Update search on September 11, 2015; 244 additional records retrieved.

Cochrane Central Register of Controlled Trials (CCRCT) via OVID

Searched March 3, 2015^*^

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <January 2015>
Search Strategy:
1. suicide/ or attempted suicide/ or suicidal ideation/ (488); 2. (suicide or suicidal or suicidality or parasuicide or self-harm or “self-directed violence” or parasuicidal).mp. (1720); 3. 1 or 2 (1720); 4. exp Suicide Prevention/ or prevention.mp. or exp Suicide Prevention Centers/ (41007); 5. exp Risk Assessment/ or risk.mp. or exp Risk Factors/ (83788); 6. (risk or screening or screen or assessment or assessments or questionnaire or questionnaires or instrument or instruments or tool or tools or scale or scales or measure or measures or correlate* or “risk stratification” or predict or predicts or predictor or predictors).mp. (272313); 7. ReACT Self Harm Rule.mp. (0); 8. Suicidal Ideation Attributes Scale.mp. (0); 9. Suicide Trigger Scale.mp. (0); 10. Cultural Assessment of Risk for suicide.mp. (0); 11. Affective Intensity Rating Scale.mp. (0); 12. Columbia Suicide Severity Rating Scale.mp. (11); 13. Edinburgh Risk of Repetition Scale.mp. (0); 14. Manchester Self Harm tool.mp. (0); 15. 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 (272313); 16. 4 or 15 (293030); 17. 3 and 16 (1319); 18. limit 17 to (peer reviewed journal and human and english language and treatment & prevention and adulthood <18+ years> and from January 2008 to Present) [Limit not valid; records were retained] (583) after deduplication 342

* Update search on September 11, 2015; 202 additional records retrieved.

SocINDEX^*^ via EBSCOHost

Searched March 6, 2015

Search Strategy:
S1 TI suicide OR suicidal OR suicidality OR parasuicide OR self-harm OR “self directed violence” OR parasuicidal; S2 DE “HEALTH risk assessment” OR DE “SUICIDAL behavior -- Risk factors”; S3 DE “SUICIDE” OR DE “SUICIDAL behavior”; S4 DE “SUICIDE prevention” OR DE “PREVENTIVE medicine”; S5 TI prevent* OR control OR risk OR screen OR screen OR assessment OR assessments OR questionnaire OR questionnaires OR instrument OR instruments OR tool OR tools OR scale OR scales OR measure OR measures OR correlate* OR “risk-stratification” OR predict OR predicts OR predictor OR predictors; S6 S1 OR S3; S7 S2 OR S4 OR S5; S8 S6 AND S7; S9 S6 AND S7 Limiters - Date of Publication: 20100101-20151231
N= (317) 223 after deduplication

* Update search on September 11, 2015; 0 additional records retrieved.

## GREY LITERATURE SEARCHES

### Search Strategies

All grey literature searches were completed on July 16, 2015.

Conferences and Organizations:
American Association of Suicidology | http://www.suicidology.org/
DOD VA Suicide Prevention Conference | http://www.suicideoutreach.org
International Suicide Summit | http://www.suicide-research.org/
American Foundation of Suicide Prevention | https://www.afsp.org/
Military Suicide Research Consortium | https://msrc.fsu.edu/
The Mental Illness Research, Education and Clinical Centers (MIRECC) | http://www.mirecc.va.gov/
Suicide Prevention Resource Center | http://www.sprc.org
Other Sources:
ClinicalTrials.gov | http://clinicaltrials.gov
NIH RePORTER | http://projectreporter.nih.gov/reporter.cfm
Journals Searched Individually:
Depression and Anxiety | http://onlinelibrary.wiley.com/journal/10.1002/%28ISSN%291520-6394
JAMA Psychiatry | http://archpsyc.jamanetwork.com/Solr/advancedSearch.aspx
Injury Prevention | http://injuryprevention.bmj.com/search
Suicide and Life-threatening Behavior | http://onlinelibrary.wiley.com/journal/10.1111/%28ISSN%291943-278X
Journal of Affective Disorders | http://www.jad-journal.com/search/advanced?seriesIssn=0165-0327&searchType=advanced&journalCode=jad
Psychiatry : Interpersonal and Biological Processes | http://www.tandfonline.com/loi/upsy20#.VTEnqpPVr0w