# SUMMARY AND DISCUSSION

Suicide is an extraordinarily complex phenomenon, associated with a range of demographic, biological, psycho-social, and clinical risk factors. Despite the number of risk factors, any given person's individual risk for suicide or suicide attempt is low.78 The complex nature of factors contributing to suicide and the relatively low population rate make interventions challenging. The complexity of suicide is reflected in the diversity of research aimed at understanding and preventing suicidal behaviors. For this review, we evaluated the evidence from RCTs of interventions aimed at reducing suicide and suicide attempts. We found articles reporting on a broad range of interventions from pharmacotherapy to psychotherapy and case management in patient populations of all ages. However, we found very few trials specifically evaluating interventions in Veteran and military populations.

Our initial searches yielded nearly 16,500 titles published on suicide treatments and risk factors since 2005. From these we identified 45 RCTs and 40 systematic reviews that provided evidence for specific treatment interventions, or referral and follow-up strategies to reduce rates of suicidal self-directed violence. Interventions included antidepressants, antipsychotics, mood stabilizers, omega-3 fatty acid supplements, CBT, and DBT, among others. Follow-up and referral strategies included postcard interventions, YSTs, and assertive community treatment. Overall, these intervention trials had methodological limitations that resulted in their providing only low strength and insufficient evidence to properly draw conclusions on the effectiveness of the various treatment interventions and follow-up/referral strategies. No interventions stood out as clearly more effective than others. This review did not evaluate any outcomes other than suicidal self-directed violence and, therefore, no additional data on potential harms and side effects was investigated.

While the gold standard for testing interventions is an RCT, the majority of the literature documenting efforts to reduce suicidal behaviors is observational in nature, and lacking in comparison or control conditions. Although information from such studies can be extremely valuable, it can also be misleading due to the potential for participant, provider, or researcher expectations about the effectiveness of the treatment under investigation to inflate positive results. As the goal of this report was to summarize the best evidence available, we focused on RCTs to minimize the risk of inflated positive results. Further, because of the noted inadequacies of proxy outcomes such as suicidal ideation for studying suicidal behavior,121 we limited our included studies to those that reported self-directed violence behaviors, specifically suicide and suicide attempts, as well as self-directed violence with undetermined intent. Though extensive observational research has been conducted on the natural course of suicide in a variety of populations including Veterans and members of the military, few RCTs have been conducted investigating the effectiveness of interventions or referral and follow-up services on reducing suicide or suicide attempts. Though a thorough review of unpublished and ongoing research is outside the scope of this report, some reviewers suggested that there is such research currently being conducted by VA investigators. The paucity of RCT research is likely due to the difficulty of studying an outcome with such low base rates, even in the highest risk populations.

As noted, we found 38 RCTs that satisfied our inclusion criteria and reported outcome data on suicides or suicide attempts. In spite of this relatively large number of trials, the data obtained provided only low strength or insufficient evidence to draw conclusions about the effectiveness of the interventions and referral/follow-up services being studied. This is primarily because interventions provided, populations studied, and comparison conditions examined in the 45 were so heterogeneous. This heterogeneity precluded meaningful comparisons across trials and quantitative combination of results from multiple trials. Therefore, each trial essentially stands alone for providing evidence related to the specific intervention being investigated. For example, though multiple studies compared psychotherapeutic interventions broadly categorized as either DBT or CBT, some studied a solely female population and all used different comparison conditions, making the combination of findings impossible.

Though large, high quality trials have the potential to stand alone as strong evidence, this was not the case with the 38 trials included in this systematic review. One limitation was inadequate blinding. Although some RCTs are more straightforward and can be easily conducted with adequate blinding techniques (e.g., pharmacological studies), many interventions and referral/follow-up services appropriate for suicide prevention are difficult if not impossible to blind in a study. Ideally, patients would be unaware of their treatment/control group status, and providers would be unaware of treatment/control group status. Also, in the case of psychotherapeutic interventions, providers' belief and expertise in providing a particular type of intervention is paramount to its effectiveness – so blinding is even more essential than it is with a pharmacologic study. Despite this challenge, it is possible to compare psychotherapeutic interventions in adequately blinded studies. An adequately blinded study would involve therapists who are experts in each of the reputable and presumably effective treatments being compared. The evaluation of effectiveness would be conducted by someone who was unaware of the intervention. For example, despite other sources of bias, the Linehan (2006) study investigating DBT provides a good example of an intervention comparison in which both patients and providers could reasonably assume that the treatments being delivered are effective.38 Thus, the risk of bias due to inadequate provider confidence in the therapy (a problem when the provider knows that he/she is delivering the placebo intervention) was minimized. These trials still require independent assessment of the outcome, though from the patient-provider standpoint, this is an example of a reasonably well-blinded study. Most RCTs of interventions and referral/ follow-up services found in this report, however, did not utilize adequate blinding procedures or comparison conditions. This inadequacy undermines the validity of the study results since patients and/or providers were likely aware of treatment assignment.

In addition to deficiencies in study design quality, a major reason that many of the trials in this report were unable to provide higher strength evidence for their findings was because they were insufficiently powered to detect an effect of the intervention. This is not uncommon when the outcome being studied has a low base rate. In many of the studies reviewed here, sample sizes were very small (in the 40s) and it is not surprising that these trials did not show any difference in outcomes between the groups. Although some trials were significantly larger, even the largest trials included in this review with sample sizes of over 1,000 participants resulted in an under-powered study design.

The issue of low base rate impacting sample size and overall strength of evidence also extends to the generalizability of the trials included in this report. For example, most of the trials included in this report examined populations with existing mental health diagnoses. This was necessary from a design standpoint in order to have a population with a reasonable likelihood of demonstrating a difference in the outcome between the interventions being studied. Though members of the military and Veterans may have mental health diagnoses, the Veteran and military population in general is not solely comprised of people with mental health diagnoses and, therefore, these results do not necessarily represent the entire Veteran and military population. Other studies applied very stringent exclusion criteria in order to have a more homogeneous participant pool, or for safety reasons due to the outcome of interest. This practice, though necessary at times, can limit generalizability and also make detection of an effect even more difficult due to the exclusion of patients with higher rates of suicidal self-directed violence.

There are many different paths to suicide, and there are many unique risk and protective factors that are difficult to study in non-Veteran/military populations. For example, we found no RCTs investigating the effectiveness of interventions to reduce self-directed violence in people diagnosed with Posttraumatic Stress Disorder or Traumatic Brain Injury, two disorders very common among Veterans and members of the military. Life stressors may be very different for this population of interest because of the duties they perform in the line of duty, the time they are potentially required to spend away from family and other support systems, and the potentially protective factors related to being a part of an organization like the military.

## LIMITATIONS

The lack of high quality trials is not a limitation of this review, per se, but rather a reflection of the available literature. However, in spite of finding few trials for our questions related to Veteran and military populations, we did not examine observational and uncontrolled studies. We felt that the best available evidence would come from trials conducted in non-Veteran/military populations rather than from observational studies conducted with our population of interest due to the inherent limitations in ability to ascribe causality to findings from non-experimental studies and studies lacking adequate control conditions. We also chose to limit the outcomes considered in this review to suicidal self-directed violence, which does not include suicidal ideation. This scoping decision could result in the exclusion of some studies related to suicidal self-directed violence if they did not collect and report data on that outcome. This review did not evaluate any outcomes other than suicidal self-directed violence, and, therefore, no additional data on potential harms and side effects were investigated. Potential harms and side effects should always be considered when evaluating the strength of evidence and considering adoption of an intervention or referral/follow-up service. Finally, it is likely that our search strategy, though based on previous systematic reviews on this topic, could have been more comprehensive and, therefore, some studies could have been left out of this review. For example, some reviewers noted that studies on other types of violent death (e.g., homicide) may have been left out of this search, even though the topics could be highly related.

## RECOMMENDATIONS FOR FUTURE RESEARCH

Due to the low base rate of the primary outcome of interest in suicide, as well as in the complexity of many of the commonly implemented interventions for suicide prevention, high quality RCTs are difficult to implement. In spite of this difficulty, however, there remains a need to further test existing and new treatment methods that could be effective in preventing suicide.

A few high quality RCTs of promising interventions could change the strength of evidence for those interventions. Additionally, large-scale studies are needed to more effectively address unanswered questions about suicide because of its low base rates. Many studies included in this report cited a lack of research funding and support for the type of large-scale clinical trials needed to investigate an outcome with such low base-rates. Though the expense might be great, well-designed, very large-scale, multi-site trials with the capability to collect data on a sufficiently large population are needed to more adequately answer questions about the effectiveness of interventions designed to decrease suicide rates. Though small-scale trials may provide important information about intervention feasibility, resources might be best spent on very large-scale investigations of the most promising interventions in order to conduct adequately powered studies that have the ability to detect an intervention effect.

Other reviews have examined common elements of the most promising suicide prevention interventions, and such non-systematic reviewing of literature could be used to help guide future research in this area.122 This field still needs investigation of interventions and referral/follow-up services that are specifically targeted to be applicable to members of the military and Veteran populations. Additionally, when considering future research as well as intervention adoption, researchers and clinicians should consider intervention costs and potential harms; these two issues were outside the scope of this review, though the articles cited reported little information on these topics, suggesting that these are areas in need of further investigation.

Given the overall limited evidence from the interventions described in this report, it is important to identify the relatively most promising interventions to help guide future research. One of the most promising interventions, Problem Solving Therapy, was reported in the Hatcher et al. study.36 This one study, conducted outside the US with a non-military/Veteran population, provides only moderate strength evidence for self-directed violence preventive effects in a specific sub-population of patients admitted to the hospital with repeated self-harm. Additionally, the findings from this current report combined with the findings from an earlier systematic review10 suggest that DBT has low strength evidence for effectiveness in self-directed violence prevention in populations with Borderline Personality Disorder. These interventions might be well-suited to future trials in VA and military settings to add to the overall evidence base, and to determine effectiveness in Veteran and military populations.

## CONCLUSIONS

Examining RCTs of interventions is the gold standard for determining relative efficacy. Thouch there are some RCTs of suicide prevention interventions, these trials are largely plagued by study design flaws and insufficient power. This is likely due to: a) the complexity of conducting high quality trials of interventions that involve psychotherapy, and b) the very low base rates of suicide and suicide attempts even in the highest risk groups. In our systematic review of the evidence related to suicide prevention interventions, we found these two issues to be paramount to the lack of strong evidence for any interventions in preventing suicide and suicide attempts.

We were most interested in RCTs related to Veteran and military populations as stated in Key Questions #1 and #3; however, we found no such trials meeting our inclusion criteria published since 2005. We, therefore, examined trials in non-Veteran/military populations in the hopes of generalizing findings to our populations of interest. The included studies covered a broad range of interventions implemented with various populations in terms of gender, age, and diagnosis. Even the broader inclusion criteria of Key Questions #2 and #4 did not provide clear answers as to which interventions or referrals and follow-up services are most effective in the prevention of suicidal or undetermined self-directed violence. Therefore, it is likely the best available evidence for interventions to prevent suicide is to use a combination of the most theoretically sound and well researched interventions available. For example, if a Veteran or member of the military is identified as being at risk for suicide, making sure that this person has adequate case management to assist with intervention attendance as well as family or other social support outside of the medical setting are both likely to be good clinical practice. Additionally, assuring that the individual has access to relatively immediate care such as inpatient hospitalization, outpatient therapy, and pharmacotherapy is also warranted depending on the individual's level of risk. Finally, providers should take into consideration which interventions are most likely to benefit the individual based on diagnosis or other relevant clinical factors (e.g., use of mood stabilizers if a patient meets criteria for Bipolar Disorder, or referral to an emotion regulation-focused psychotherapy intervention such as DBT if the patient meets criteria for Borderline Personality Disorder). Overall, the intervention and referral/follow-up service studies that were included in this report were quite complex and appeared very comprehensive in nature; such a comprehensive and multifaceted approach to suicide prevention care for Veterans and members of the military appears well warranted.