# RESULTS

## LITERATURE FLOW

We reviewed 16,426 titles and abstracts from the electronic search, and an additional 92 from reference mining for a total of 16,518 references. After applying inclusion/exclusion criteria at the abstract level, 16,110 references were excluded. We retrieved 408 full-text articles for further review and another 336 references were excluded. We identified a total of 85 references for inclusion in the current review, including 38 RCTs (reported in 47 publications) and 23 systematic reviews (reported in 25 publications). We grouped the studies by key question, type of intervention, route of administration, and clinical condition. Figure 2 details the number of references related to exclusion criteria and publication type.

Figure 2 Literature Flow Chart^a^

^a^ Modified from the PRISMA flow diagram.79

## KEY QUESTION #1 What is the effectiveness of specific interventions for reducing rates of suicidal self-directed violence in military and/or Veteran populations?

We did not find any RCTs of suicidal self-directed violence prevention interventions in military and/or VA health care settings.

## KEY QUESTION #2 What lessons can be learned from self-directed violence prevention intervention research conducted outside of VA or military settings that can be applied to Veteran and/or military populations?

### Pharmacotherapy Interventions

#### Summary of Findings

##### Antidepressants

The conclusions of three systematic reviews with similar key questions to the current report were consistent in relation to antidepressants.9-11 All found that available evidence from trials does not show a benefit for reducing suicide, but caution that rates of suicide may have been too low to detect differences. Although observational studies show a correlation between increasing prescription rates and decreasing suicide rates, this evidence is considered lower strength than evidence obtained from RCTs or meta-analyses.

Findings from antidepressant trials in non-Veteran/military populations were consistent with previous reviews on the topic, and did not provide sufficient evidence to make a strong conclusion about the effectiveness of antidepressants in reducing suicidal self-directed violence. We identified nine trials (reported in 10 publications) that evaluated antidepressant medications. Comparisons included various combinations of antidepressant medications versus placebo;18-23 one antidepressant versus another;24, 25 antidepressant therapy versus cognitive behavioral therapy (CBT);23 and antidepressant therapy with and without CBT.19, 21, 26, 27 Many studies reported no suicidal self-directed violence in either group. Because of the short duration and low participant numbers, many of these studies would not have had the statistical power and duration of follow-up to allow the medication to affect a change in suicide rates. Therefore, they are felt to be of low strength, and are insufficient for determining the effectiveness of various combinations of antidepressant medications for reducing suicides.

##### Atypical Antipsychotics

The conclusions of three systematic reviews with similar key questions to the current report were consistent in relation to atypical antipsychotic medications.9-11 The three reports included different studies of antipsychotic medications. Overall, they report positive findings from trials of flupenthixol, clozapine, and fluphenazine, though caution that findings are based on small samples of patients in very few studies.

We found three trials that reported on the effectiveness of quetiapine (1 trial)28 or adjunctive aripiprazole (2 trials in 3 publications)29-31 in reducing suicide deaths. These trials were six to eight weeks in duration and none had any suicides reported during the follow-up period. The quetiapine trial reported one suicide attempt in each group (treatment and intervention). Therefore, we concluded there was insufficient evidence to determine antisuicidal benefit. Notably, the Mann et al. review found an antisuicidal effect of clozapine, an atypical antipsychotic medication.10

##### Mood Stabilizers

The conclusions of three systematic reviews with similar key questions to the current report were consistent in relation to atypical mood stabilizers.9-11 The three reports included different studies of mood stabilizers. The systematic reviews report different results related to mood stabilizing medications. Gaynes et al. report no reduction in suicide rates based on one trial of lithium, whereas Mann et al. and NICE report some non-significant reductions in suicide rates for patients receiving lithium.9-11

The two trials of mood stabilizers compared lithium versus valproate (2.5 years)32 and lithium versus citalopram (8 weeks).33 These trials did not report any occurrences of suicidal selfdirected violence during the course of the trials. The Mann et al. review found an antisuicidal effect for lithium compared to carbamazepine and amitriptyline in trials published prior to June, 2005.^10^ Thus, these trials provided insufficient evidence to draw conclusions about the comparative effectiveness of mood stabilizers in preventing suicidal self-directed violence.

One study conducted in a country outside the scope of this review was suggested for inclusion by reviewers.34 This study, had it been included in our results, provided insufficient evidence for the effectiveness of lithium in prevention of suicidal self-directed violence when compared to placebo.

##### Omega-3 Fatty Acid Supplementation

One trial of omega-3 fatty acid supplementation for 12 weeks did not have any suicide deaths in either group.35

#### Studies of Efficacy

##### Systematic Reviews

We identified 20 new relevant systematic reviews (in 22 publications) that had been published subsequent to Mann et al.10, 80-101 However, the utility of the conclusions from these systematic reviews was limited due to scope differences. Specifically, in all cases for our outcomes of interest (i.e., suicidal self-directed violence), conclusions from existing new reviews were based on groups of primary studies with a broader range of designs (i.e., observational), publication dates (i.e., before 2005) and from a broader range of countries than our focus of the US, United Kingdom, Canada, New Zealand, and Australia. Therefore, we were only able to use existing new reviews as an additional source of identifying new primary RCTs. Appendices F and G document the quality assessment of the systematic reviews found in our search, as well as data from the RCTs included in the reviews.

We found three systematic reviews that addressed key questions that are similar to those addressed in this report,9-11 and a summary of findings from these reports are included in Appendix H. Overall, these three systematic reviews report that all findings are based on few studies with limited sample sizes, some methodological quality concerns, and short term follow-up assessment periods; therefore, pharmacotherapy findings should be interpreted with caution. The findings from the Mann et al. report, which was conducted with a similar search strategy to this report with non-overlapping search dates, are combined with the results from our search and presented in the following results section and associated tables.

##### Randomized Controlled Trials (RCTs)

The majority of trials focused on patients with depression, but half specifically excluded those who posed a suicidal risk. The majority of trials did not involve the necessary sample sizes (mean, 284.4 patients; standard deviation, 177.8) or follow-up durations (median, 8 weeks; range, 4 weeks to 2.5 years) required to adequately evaluate risk of suicide attempts or suicides. Therefore, these trials generally provided inadequate to low strength evidence for drawing conclusions about risk of suicide attempts and suicides. Data abstraction, risk of bias assessment, and strength of evidence rating tables are included in Appendices J through L.

We also report a summary of sample sizes, outcome definitions and results from all RCTs included in this review, along with a description of the purpose of the study in order to examine possible relationships among study intent, design and outcome. Of particular interest was whether studies which were designed to treat suicidal self-directed violence might be better powered to detect effects of such a low base rate outcome when compared to studies designed to treat another related but more common outcome such as depression. These results are presented in Appendix I for studies investigating pharmacotherapy interventions. Notably, there does not appear to be a strong relationship between sample size (and, by extension, statistical power) and whether or not the studies were reportedly designed to treat suicidal self-directed violence versus other outcomes.

##### Antidepressants

The conclusions of the Mann et al., Gaynes et al., and NICE reports were similar in relation to antidepressants.9-11 All found that available evidence from trials does not show a benefit for reducing suicide, but caution that rates of suicide may have been too low to detect differences. Although observational studies show a correlation between increasing prescription rates and decreasing suicide rates, this evidence is considered lower strength than evidence obtained from RCTs or meta-analyses.

Antidepressants versus Placebo. The Mann review found that antidepressants were not associated with a benefit over placebo for suicidal self-directed violence.10

The majority of the RCTs published subsequent to the Mann review provided insufficient evidence for drawing conclusions about associations between antidepressants and suicidal self-directed violence.18-22 The strength of this evidence was limited both by trials that apparently did not assess suicide deaths18, 20 and those that did, in which small sample sizes and/or inadequate follow-up durations likely led to a lack of observed events.19, 21, 22 The only trial that reported any suicide deaths had low potential for bias, but still provided low strength evidence of no significant difference between paroxetine 38.8 mg (mean) and placebo in suicide deaths at week eight among 180 civilian adults with moderate to severe depression (0.8% compared with 0, P not reported).23 RCTs published subsequent to the Mann review also provided low strength evidence of no significant difference between escitalopram 13.2 mg (mean),20 fluoxetine 32.8 mg (mean maximal),19, 21 or paroxetine 10 mg18 compared with placebo in suicide attempts in depressed children and adolescents.

Antidepressants versus Antidepressants. We included two RCTs that directly compared different antidepressant medication regimens.24, 25 These trials provided insufficient evidence to draw conclusions about differential effects on risk of suicide death due to insufficient statistical power and a lack of observed events. However, one trial with an unclear risk of bias provided low strength evidence that escitalopram, taken in combination with (0 events) or without bupropion sustained-release (0 events), significantly reduced risk of suicide attempts at seven months compared with venlafaxine extended release plus mirtazapine (2.3%, P=0.0162) when taken in civilian adults with either recurrent or chronic major depressive disorder.25

Antidepressants Alone versus Antidepressants plus CBT. We included three RCTs with unclear risk of bias that compared antidepressants alone versus antidepressants plus CBT in adolescents with major depressive disorder.19, 21, 26, 27 These trials provided insufficient evidence to draw conclusions about prevention of suicide deaths as only one trial reported assessment of suicide deaths, and there were no observed events for fluoxetine alone or fluoxetine plus CBT after 36 weeks in 216 adolescents with major depressive disorder.19, 21 Additionally, compared to taking antidepressants alone, these trials provided low strength evidence that combination treatment with CBT plus antidepressants did not significantly improve protective effects against suicidal self-injury adverse events at 12 weeks,26 suicidal acts at 28 weeks,27 or suicide attempts at 36 weeks.19, 21 In one of these trials,26 subgroup analyses found that participants with higher than median baseline suicidal ideation were more likely to experience a self-harm event (suicidal or non-suicidal) if they were treated with venlafaxine than with a Selective Serotonin Reuptake Inhibitor (SSRI), and participants who received a benzodiazepine in addition to an antidepressant were more likely to experience suicidal self-injury adverse events.

Antidepressants versus CBT. We included one RCT with an unclear risk of bias that provided low-strength evidence of no significant difference between paroxetine 38.8 mg (mean) and cognitive therapy in suicide deaths at week eight among 180 civilian adults with moderate to severe depression (0.8% compared with 0, P not reported).23

##### Atypical Antipsychotics

The Mann et al., Gaynes et al., and NICE reports included different studies of antipsychotic medications.9-11 Overall, they report positive findings from trials of flupenthixol, clozapine, and fluphenazine, though caution that findings are based on small samples of patients in very few studies. The Mann review found an antisuicidal effect for clozapine in two randomized, controlled trials in adults with schizophrenia spectrum disorders.10 These findings are summarized in the strength of evidence tables provided in Appendix L and provide insufficient to low strength evidence for the suicidal self-directed violence preventive effect of clozapine for adults with schizophrenia spectrum disorders.

Trials of quetiapine28 and aripiprazole29-31 published subsequent to the Mann review did not detect benefit for suicide prevention in civilians with mood disorders. In fact, no suicides occurred in any of the three trials. This is likely because these trials: 1) enrolled lower-risk patients who would be expected to have a low base rate of suicide (protocols specified exclusion of patients that posed a suicidal risk); 2) involved inadequate follow-up durations to detect such a low base rate of suicide (6-8 weeks); and 3) had relatively small treatment group sample sizes that were likely underpowered to detect a low base rate of suicide (range, 176 to 191 patients).

Risk of bias was low in the placebo-controlled trial of quetiapine monotherapy (300 or 600 mg) in 542 outpatients with bipolar depression.28 During the eight-week trial, only two patients attempted suicide (1 in each of the quetiapine groups) and there were no suicides. Risk of bias was unclear in the two identically-designed, placebo-controlled trials of aripiprazole (mean dose range, 11.0 mg/day to 11.8 mg/day) as adjunctive treatment to standard antidepressant therapy in the treatment of 743 patients with major depressive disorder who have shown an incomplete response to the same antidepressant therapy.29-31 There were no suicides during the six-week treatment periods in either trial.

##### Mood Stabilizers

The Mann review found an antisuicidal effect for lithium compared to carbamazepine and amitriptyline in a long-term (2.5 years) randomized, controlled trial of 378 German adults with affective disorders, providing insufficient to low strength evidence for the suicidal self-directed violence preventive effect of lithium for adults with affective disorders.10

However, two RCTs of lithium published subsequent to the Mann review did not detect benefit for suicide prevention in civilians with mood disorders.32, 33 There was no significant difference between lithium 0.6–1.0 mEq/dl and valproate 45–125 μg/ml detected over 2.5 years in 98 civilian bipolar patients in a major depressive or mixed episode who had a past suicide attempt.32 There were no suicide deaths and no significant difference between lithium and valproate in suicide attempts (12% compared with 16%; P-value not reported) or in time to suicide attempt (log-rank test). Risk of bias was unclear in this trial due to insufficient information to permit firm judgments for the majority of the bias domains. Our uncertainty about the impact of the incomplete outcome data raised the most doubt about the results of this trial. The loss to follow-up was 26 percent and somewhat higher in the lithium group (31% compared with 20%), and those lost to follow-up had more previous psychiatric hospitalizations and were more likely to report a history of childhood abuse. However, since neither of those potential risk factors has strong empirical evidence of association with suicide attempts or death and we are also uncertain whether the proportion of missing data is enough to induce a clinically relevant bias in effect size, we have fair confidence in the trial's results.

In an RCT with low potential for bias, there were no suicide deaths or attempts at four weeks with citalopram 20 mg once daily, taken with or without lithium 300 mg, in 80 severely depressed, civilian adults.33

Although both trials enrolled high-risk participants and the 2.5-year follow-up period used in one of the trials was sufficiently long to capture suicide outcomes,32 neither trial was adequately powered to detect differences in suicide attempts or deaths.

Finally, one study conducted in the countries outside the scope of this review was suggested for inclusion by reviewers.34 This study, had it been included in our results, was judged to have a high risk of bias due to having a high loss to follow-up, baseline differences between groups, and other factors. The trial compared lithium to placebo, resulting in a suicide death rate of 0/84 (0%) in the intervention group and 3/83 (3.6%) in the control group, though these differences were not statistically significant; the combined sample size was 167. The authors report similar results between the two groups in terms of suicide attempts. Overall, the results from this study provide insufficient evidence for the effectiveness of lithium in prevention of suicidal self-directed violence when compared to placebo.

##### Omega-3 Fatty Acid Supplementation

Evidence is insufficient to draw conclusions about the antisuicidal effects of omega-3 fatty acid supplementation.35 In an RCT with low potential for bias, there were no suicide deaths at 12 weeks with eicosapentaenoic acid 1.2 mg plus docosahexaenoic acid 0.9 mg or placebo in 49 civilian adults who presented to an academic teaching hospital in Dublin, Ireland after an act of repeat self-harm.

### Psychotherapy Interventions

#### Summary of Findings

All psychotherapy trials meeting criteria for inclusion in this review were sufficiently heterogeneous in terms of type of treatment, duration of treatment, and population characteristics to preclude combination or quantitative comparison. Therefore, psychotherapy trials are grouped for discussions by population: those conducted in patients with Borderline Personality Disorder, recent suicide attempts, a psychotic spectrum disorder, and depression or dysthymia.

Three previously published systematic reviews on this topic all report overall insufficient to low strength of evidence for the effectiveness of any psychotherapeutic interventions in the prevention of self-directed violence.9-11 The authors of these reviews describe these limitations as being due to basing findings on very few studies with limited sample sizes, some methodological quality concerns, and short term follow-up assessment periods, as well as difficulties studying such low base-rate outcomes.

##### Psychotherapy Interventions for People with Borderline Personality Disorder

Psychotherapy results reported in the Mann et al. systematic review included insufficient to low strength evidence supporting the suicidal self-directed violence preventive effects of Dialectical Behavior Therapy (DBT) and psychoanalytically oriented partial day hospitalization for people with Borderline Personality Disorder.

Three RCTs provided insufficient evidence to draw conclusions about prevention of suicide deaths in populations with Borderline Personality Disorder, largely because no or very few suicides occurred during the trials. One trial showed a significant reduction in suicide attempts with Mentalization Based Treatment (MBT) compared to Structured Clinical Management (SCM),37 as did a trial comparing DBT with community treatment by experts.38 Three other studies showed no significant benefit in suicide attempt prevention for Systems Training for Emotional Predictability and Problem Solving (STEPPS) versus treatment as usual,39 CBT specific to Cluster B personality disorders versus treatment as usual,40, 41 or DBT versus general psychiatric management.42

##### Psychotherapy Interventions for People with Recent Suicide Attempts, Recent Self-Harm Incidents, or Imminent Risk

Psychotherapy results reported in the Mann et al. systematic review included insufficient to low strength evidence supporting the suicidal self-directed violence preventive effects of cognitive therapies, cognitive therapy, interpersonal psychotherapy, and problem-solving therapy.

The strongest evidence (moderate strength) obtained from primary studies included in this report comes from a trial of problem-solving therapy in addition to usual care versus usual care alone for patients with recent suicide attempts.36 This trial showed no significant benefit of the intervention compared to usual care when examining a patient population of people hospitalized for a wide variety of self-harming behaviors; patients participating in DBT were excluded from the study. The authors report examination of an a priori hypothesis to see whether there were different treatment effects for patients whose index hospitalization was the first time they were hospitalized for self-harm behavior versus patients who were repeatedly hospitalized for self-harm behavior prior to the intervention. They report that the treatment showed no significant effect in patients who were hospitalized for the first time; however, there were significantly fewer re-presentations to the hospital for self-harm behaviors for both consenting and all (consenting and non-consenting, i.e., intention-to-treat [ITT] analysis) patients when only patients who had repeated hospitalizations for self-harm prior to the intervention were considered. There were also significantly fewer participants who self-reported engaging in self-harm behaviors from the group of consenting patients when only patients who had repeated hospitalizations for self-harm prior to the intervention were considered, though this self-report data was not able to be obtained from non-consenting patients for the ITT analysis. The authors report that analyses adjusting for treatment location and therapist nesting had no effect on the results. Finally, a similar pattern of statistically significant results for patient groups was reported for time to re-presentation to the hospital for self-harm behaviors, with patients hospitalized for repeat self-harm in the treatment group showing a significant improvement in time to re-presentation when compared to patients in the control condition; these results were significant for both consenting patients as well as the combined group of consenting and non-consenting patients (i.e., the ITT analysis).

Few trials reported on prevention of suicide deaths as the outcome of psychotherapy interventions, and of those that did, most were insufficiently powered to detect an effect of the intervention. One study conducted a comparison among people with recent suicide attempts, self-harm incidents, or imminent risk.43 This trial had several design flaws that contribute to a high potential for bias: non-randomization, baseline differences among the groups, non-blinding, and differing drop-out rates among the groups. Therefore, there was insufficient evidence to draw conclusions about the psychotherapy comparison. Two other studies of people presenting with repeat self-harm reported no suicide events in either treatment or control groups for group therapy,44 and for intensive case management.45 Other studies evaluated inventions in similar populations (prior suicidal self-directed violence). A study of Attachment-Based Family Therapy versus Enhanced Usual Care showed a reduction in suicide attempts, though design flaws limit the ability to draw a firm conclusion about the results.46 Likewise, studies comparing Collaborative Assessment and Management of Suicidality (CAMS) versus Enhanced Care As Usual (E-CAU) and skills-based intervention versus a supportive therapy control condition did not use sufficient methodological rigor to enable firm conclusions about effectiveness.47,48 Notably, a study of adolescent group therapy compared to routine care resulted in fewer instances of self-harm in the routine care group indicating the possibility of iatrogenic effects in the group treatment condition; however, design flaws in this study preclude the ability to draw firm conclusions based on the results.49 Finally, one study compared three conditions: CBT, problem-solving therapy, and treatment as usual. This study had few patients and methodological limitations and, therefore, provides insufficient evidence related to any of the interventions being investigated.50

##### Psychotherapy Interventions for People with a Psychotic Spectrum Disorder

One study comparing CBT versus supportive counseling in patients with a psychotic spectrum disorder had an unacceptably high risk of bias because therapists were not blinded and delivered both interventions to the participants.51 This trial provided insufficient evidence to draw definitive conclusions about the effectiveness of the intervention.

##### Psychotherapy Interventions for People with a Depression or Dysthymia

One trial comparing the Improving Mood: Promoting Access to Collaborative Treatment (IMPACT) intervention (including a comprehensive depression case management and treatment component) versus usual care in people with depression or dysthymia had methods that suggested an unclear risk of bias.52 This trial provided insufficient evidence to draw definitive conclusions about the effectiveness of the intervention.

#### Studies of Efficacy

##### Systematic Reviews

Our search identified 24 new systematic reviews relevant to psychotherapy published in 25 articles subsequent to Mann 2005.^14, 86, 87, 89, 90, 93, 94, 96, 98, 100, 102-116^ Of these, 13 were rated high quality according to the Oxman and Guyatt validation index15 and are included in the summary below.14, 87, 98, 102, 104, 106, 107, 109, 111-115 Eleven were rated lower quality and are not discussed further in this report.

Of the 13 high quality systematic reviews, most included only primary studies that were outside the scope of this review: primary studies with a broader range of study designs (i.e., observational studies); publication dates (i.e., before 2005); and from a broader range of countries than our focus on the US, United Kingdom, Canada, New Zealand, and Australia. Of the potentially eligible RCTs identified from the high quality systematic reviews, only one contributed relevant data related to psychotherapeutic interventions and is included in our review of primary studies.52 Appendices M and N summarize quality assessment and data abstraction from the included systematic reviews.

In addition to these reviews, we included and summarized findings from three other systematic reviews with similar key questions to this current report. These three previously published reports on this topic all report findings of psychotherapeutic interventions with different combinations of studies into categories, making comparisons across reports difficult.9-11 Results are reported in Appendix S, and all three reports note the overall insufficient to low strength of evidence for the effectiveness of any psychotherapeutic interventions in prevention of self-directed violence. The authors of the other reviews describe these limitations as being due to basing findings on very few studies with limited sample sizes, some methodological quality concerns, and short term follow-up assessment periods, as well as difficulties studying such low base-rate outcomes. Overall, combination of findings from multiple psychotherapy studies compared to treatment as usual resulted in low strength evidence of the effectiveness of these interventions in prevention of self-directed violence. Individual psychotherapy results included mixed findings related to cognitive therapies, positive findings related to DBT for people with Borderline Personality Disorder, positive findings for interpersonal psychotherapy, null findings for outpatient day hospitalization, positive findings for problem-solving therapy, positive findings for psychoanalytically oriented partial day hospitalization for people with Borderline Personality Disorder, and positive findings for transference-focused psychotherapy. Notably, these results were presented in the previous reports as coming from very few studies with small sample sizes, many methodological flaws, and short-term follow-up assessment periods, suggesting that all findings are of insufficient to low strength and should be interpreted with caution. The findings from the Mann et al. report, which was conducted with a similar search strategy to this report with non-overlapping search dates, are combined with the results from our search and presented in the following results section and associated tables.

##### Randomized Controlled Trials (RCTs)

Appendices Q through S summarize quality assessment, risk of bias, and strength of evidence ratings from the included primary studies.

We also report a summary of sample sizes, outcome definitions, and results from all RCTs included in this review along with a description of the purpose of the study in order to examine possible relationships among study intent and design, and outcome. Of particular interest was whether studies which were designed to treat suicidal self-directed violence might be better powered to detect effects of such a low base rate outcome when compared to studies designed to treat another related but more common outcome such as depression. These results are presented in Appendix O for studies investigating psychotherapy interventions. Notably, there does not appear to be a strong relationship between sample size (and, by extension, statistical power) and whether or not the studies were reportedly designed to treat suicidal self-directed violence versus other outcomes.

##### Psychotherapy Interventions for People with Borderline Personality Disorder

The Mann review found that both psychoanalytically-oriented partial hospitalization and DBT reduced suicidal self-directed violence compared with standard after care.10 Notably, these results were presented in the Mann et al. report as coming from very few studies with small sample sizes, methodological flaws, and short-term follow-up assessment periods, suggesting that these findings should be interpreted with caution. Overall, these studies provide insufficient to low strength evidence for the effectiveness of the interventions.

Evidence published since the Mann review included six trials investigating the relative effectiveness of interventions for the treatment of Borderline Personality Disorder in reducing suicidal self-directed violence. Due to the heterogeneity of study populations and interventions, the evidence from each study is reported separately. Detailed descriptions of the various interventions are contained in the data abstraction tables (Appendix Q).

Two studies (Bateman et al., 2008 and Bateman et al., 2009) examined MBT, though the former compared this treatment to treatment as usual, and the latter used SCM as the control condition.37, 117 Compared to SCM, there is low-strength evidence that MBT significantly reduced the proportion of patients with life-threatening suicide attempts after 18 months (2.8% compared with 25.4%; effect size of d = .65) and those with severe self-harm incidents (23.9% compared with 42.9%; effect size of d = .62).37 However, the trial that compared MBT with SCM provided insufficient evidence to draw conclusions about their relative effectiveness in self-directed violence prevention due to the presence of an unacceptably high risk of bias, as well as imprecise data.117

Blum and colleagues (2008) conducted an RCT of STEPPS versus treatment as usual.39 This trial provides low-strength evidence of no significant between-group differences in time to first suicide attempt and time to first self-harm incidents.

Two articles (Davidson et al., 2006 and Davidson et al., 2010) describe an RCT of CBT specific to Cluster B personality disorders versus treatment as usual.40, 41 This trial of 106 participants provides low-strength evidence that there is a non-significant effect of the intervention on number of subjects with suicidal acts over six years (56% compared with 73%; Odds ratio [OR] 0.37; 95% Confidence Interval [CI], 0.10 to 1.38) and number of episodes of suicidal acts (1.88 compared with 3.03; MD 1.26; 95% CI, -0.06 to 2.58).40, 41

Linehan and colleagues (2006) investigated the effectiveness of a DBT intervention versus community treatment by experts in a sample of 111 adult women.38 However, as there were no suicide deaths in this trial, there is insufficient evidence to draw conclusions about the relative effectiveness of suicide death prevention. The study provides low strength evidence of a significantly lower suicide attempt rate for DBT (23.1% compared with 46%; Hazard ratio [HR] 2.66, p = .005).

Another study of DBT by McMain and colleagues (2009) compared the treatment to general psychiatric management.42 Similar to the evidence from the Linehan et al. (2006) study, this trial provides insufficient evidence to draw conclusions about differential effects on risk of suicide death due to a lack of observed events. However, this study provides low strength evidence for a non-significant treatment effect on mean number of suicide attempts and self-harm at 12 months (4.29 compared with 12.87).

##### Psychotherapy Interventions for People with Recent Suicide Attempts, Recent Self-Harm Incidents, or Imminent Risk

Psychotherapy results reported in the Mann et al. systematic review included insufficient to low strength evidence supporting the suicidal self-directed violence preventive effects of cognitive therapies, interpersonal psychotherapy, and problem-solving therapy. Notably, these results were presented in the Mann et al. report as coming from very few studies with small sample sizes, methodological flaws, and short-term follow-up assessment periods, suggesting that all findings are of insufficient to low strength and should be interpreted with caution.

We included seven RCTs of psychotherapy interventions for people with recent suicide attempts, recent self-harm incidents, or imminent risk.36, 43-45, 47, 48, 50 Only three of the trials reported an assessment of suicide deaths, but all provided only insufficient to low strength evidence because of lack of statistical power and methodological flaws.43-45

A large (N = 1094) RCT conducted by Hatcher and colleagues (2011) in New Zealand provided moderate strength of evidence of a non-significant effect of problem-solving treatment plus treatment as usual versus treatment as usual on the outcomes of re-presentation to the hospital for self-harm (14.2% vs 17.1%; Relative risk [RR] 0.17; 95% CI, -0.24 to 0.44) and self-reported self-harm (27.4% vs 32.7%; RR 0.16; 95% CI, -0.13 to 0.38).36 However, the authors also report examination of an a priori hypothesis to see whether there were different treatment effects for patients whose index hospitalization was the first time they were hospitalized for self-harm behavior versus patients who were repeatedly hospitalized for self-harm behavior prior to the intervention. They report that the treatment showed no significant effect in patients who were hospitalized for the first time; however, there were significantly fewer re-presentations to the hospital for self-harm behaviors for both consenting and all (consenting and non-consenting, i.e., ITT analysis) patients when only patients who had repeated hospitalizations for self-harm prior to the intervention were considered. There were also significantly fewer participants who self-reported engaging in self-harm behaviors from the group of consenting patients when only patients who had repeated hospitalizations for self-harm prior to the intervention were considered, though this self-report data was not able to be obtained from non-consenting patients for the ITT analysis. The authors report that analyses adjusting for treatment location and therapist nesting had no effect on the results. Finally, a similar pattern of statistically significant results for patient groups was reported for time to re-presentation to the hospital for self-harm behaviors, with patients hospitalized for repeat self-harm in the treatment group showing a significant improvement in time to re-presentation when compared to patients in the control condition; these results were significant for both consenting patients as well as the combined group of consenting and non-consenting patients (i.e., the ITT analysis).

We also included RCTs that compared CAMS versus E-CAU in a population of adults with a recent suicide attempt or imminent risk,47 a skills-based intervention versus a supportive therapy control condition,48 CBT compared to problem solving therapy compared to treatment as usual,50 and intensive case management with a therapy component,45 but all trials provided insufficient evidence to draw conclusions about self-directed violence prevention due to an unacceptably high risk of bias.

A study of Attachment-Based Family Therapy versus Enhanced Usual Care resulted in fewer low lethality suicide attempts in the treatment condition (11% in the treatment and 22% in the control group), though a low strength evidence rating limits the ability to draw a firm conclusion about the results.46

Notably, a study of group therapy for adolescents between 12 and 16 years of age resulted in an 88 percent incidence of repeated self-harm after 12 months compared to a 71 percent incidence of self-harm (p = .07) in the routine care condition, indicating the possibility of iatrogenic effects in the group treatment condition. This study provided low strength evidence, however, and, therefore, conclusions about the possibility of iatrogenic effects are tentative.49 Another, more recent study of group therapy conducted by Green and colleagues provides low strength evidence,44 though in spite of a relatively large sample size (N = 366), this study reported no suicide deaths among all participants, and only one incident of self-harm with severe injury in the treatment group compared to two instances in the control group.

##### Psychotherapy Interventions for People with a Psychotic Spectrum Disorder

We included one RCT that compared CBT with supportive counseling in 278 participants.51 However, despite the relatively large sample size, this trial had an unacceptably high risk of bias and provided insufficient evidence to draw conclusions about the relative effectiveness of the two treatments in self-directed violence prevention.

##### Psychotherapy Interventions for People with Depression or Dysthymia

An RCT of the IMPACT intervention included a comprehensive depression case management and treatment component compared to usual care in a population of adults age 60 and older.52 In spite of the large sample size of this trial (N=1801) with unclear risk of bias, it provides insufficient evidence to draw conclusions about differential effects on risk of suicide death due to a lack of observed events.

## KEY QUESTION #3 What is the effectiveness of referral and follow-up services (e.g., strategies designed to provide referrals, improve referral follow-through and attendance, etc.) for reducing rates of suicidal self-directed violence in military and/or Veteran populations?

We did not find any new RCTs on self-directed violence referral and follow-up services in military and/or VA health care settings.

## KEY QUESTION #4 What lessons can be learned from research on self-directed violence referral and follow-up services conducted outside of VA or military settings that can be applied to Veteran and/or military populations?

### Summary of Findings

The three previously published reports on this topic all report overall insufficient to low strength of evidence for the effectiveness of any referral and follow-up services in prevention of self-directed violence.9-11 Specific findings from the three reports include positive results from studies on case management/care coordination and 24-hour contact with a mental health professional. Mixed reports of findings came from studies on emergency contact cards and postal contact. Null findings were reported from studies investigating intensive psychosocial follow-up, telephone follow-up, and video education plus family therapy. Notably, these results were presented in the previous reports as coming from very few studies with small sample sizes, many methodological flaws, and short-term follow-up assessment periods, suggesting that all findings are of insufficient to low strength and should be interpreted with caution.

Of the primary studies included in this review, three studies of postcard interventions to decrease repeated self-harm showed mixed results.53-55 Two studies of Youth-Nominated Support Team (YST) interventions combined with usual care did not significantly reduce risk of suicide attempts or death in suicidal adolescents.56, 57 One study of assertive community treatment compared with community mental health care in difficult-to-engage adults with serious mental illness showed no reduction in suicide deaths or deliberate self-harm incidents.58 Finally, one trial of a depression care management program resulted in no significant changes in the suicide mortality rate of older adults in primary care settings.59 However, all these studies were given low strength of evidence ratings and thus limit conclusions about the effectiveness of these interventions.

### Studies of Efficacy

#### Systematic Reviews

We identified nine new systematic reviews relevant to referral and follow-up services published in 10 articles subsequent to Mann 2005.^14, 90, 96, 103, 106, 109, 112, 115, 118, 119^ Of these, six were rated high quality according to the Oxman and Guyatt validation index15 and are included in the summary below.14, 106, 109, 112, 115, 118 Three were rated lower quality and are not discussed further in this report.

Of the six high quality systematic reviews, three included only primary studies that were outside the scope of this review: primary studies with a broader range of studies designs (i.e., observational studies); publication dates (i.e., before 2005); and from a broader range of countries than our focus on the US, United Kingdom, Canada, New Zealand, and Australia. The other three high quality systematic reviews included a total of three eligible RCTs.54, 55, 58 Therefore, we were only able to use existing new reviews as an additional source of identifying new primary RCTs. These three RCTs are included as primary studies in our review.

Appendices T and U present quality assessment of the systematic reviews and data abstraction of the primary studies obtained from the systematic reviews.

Three previously published reports on this topic with similar key questions to the current report all report findings of referral and follow-up services with different combinations of studies into categories, making comparisons across reports difficult.9-11 Results are reported in Appendix V, and all three reports note the overall insufficient to low strength of evidence for the effectiveness of any referral and follow-up services in prevention of self-directed violence. Specific findings from the three reports include positive results from studies on case management/care coordination and 24-hour contact with a mental health professional. Mixed reports of findings came from studies on emergency contact cards and postal contact. Null findings were reported from studies investigating intensive psychosocial follow-up, telephone follow-up, and video education plus family therapy. Notably, these results were presented in the three systematic reviews as coming from very few studies with small sample sizes, methodological flaws, and short-term follow-up assessment periods, suggesting that all findings are of insufficient to low strength and should be interpreted with caution. The findings from the Mann et al. report, which was conducted with a similar search strategy to this report with non-overlapping search dates, are combined with the results from our search and presented in the following results section and associated tables.

#### Randomized Controlled Trials (RCTs)

Appendices X through Z present data abstraction, risk of bias assessment, and strength of evidence grading of the primary studies included in this review.

We also report a summary of sample sizes, outcome definitions, and results from all RCTs included in this review along with a description of the purpose of the study in order to examine possible relationships among study intent and design, and outcome. Of particular interest was whether studies which were designed to treat suicidal self-directed violence might be better powered to detect effects of such a low base rate outcome when compared to studies designed to treat another related but more common outcome such as depression. These results are presented in Appendix W for studies investigating referral and follow-up services. Notably, there does not appear to be a strong relationship between sample size (and, by extension, statistical power) and whether or not the studies were reportedly designed to treat suicidal self-directed violence versus other outcomes.

##### Postcard Interventions

The Mann review included one RCT of 843 persons which found a significantly lower suicide rate for at least two years in those who were contacted by letter at least four times a year compared to those who received no further contact after discharge following hospitalization due to a depressive or suicidal state.10 This trial provides insufficient to low strength evidence for the effectiveness of postcard interventions in preventing suicidal self-directed violence.

However, findings from two RCTs (in three publications) with unclear risk of bias provided low strength evidence of mixed results regarding effects of postcard interventions on repeat self-harm.53-55 In 772 adults discharged from a Newcastle, Australia hospital after deliberate self-poisoning, compared to standard treatment alone, eight postcards sent over 12 months significantly reduced the cumulative number of repeat episodes of deliberate self-poisoning both at 12 months (Incident Risk Ratio [IRR] 0.55; 95% CI, 0.35 to 0.87) and at 24 months (IRR 0.49; 95% CI, 0.33 to 0.73), but did not reduce the proportion of patients with repeat deliberate self-poisoning at either time point.54, 55 However, at both 12 months and 24 months, subgroup analyses found that the significant reduction in cumulative number of repeat episodes of deliberate self-poisoning with the postcard intervention was observed only in women and not in men.

In a later trial of 327 individuals aged 16 and older who were discharged from Christchurch Hospital in New Zealand following self-harm of attempted suicide, compared to treatment as usual and after adjustment for prior self-harm, six postcards mailed over 12 months did not significantly reduce the total number of self-harm re-presentations (IRR 1.07; 95% CI, 0.80 to 1.43) or total proportion of patients who re-presented for self-harm (OR 0.97; 95% CI, 0.58 to 1.62).53

##### Youth-Nominated Support Team (YST)

The Mann review did not include any RCTs of YST interventions.10 However, we found two RCTs with unclear risk of bias that provided low-strength evidence that, compared to treatment as usual only, adding YST did not significantly reduce suicide deaths or attempts in suicidal, psychiatrically hospitalized adolescents in the US.56, 57

In general, the YST intervention supplements usual care by providing youth-nominated support persons who maintain regular contact with the patients following hospitalization. In the first trial, YST-I, adolescents had the option of including one peer in the support team and the regular contact was maintained for six months, but there was a trend toward a higher proportion of patients with one or more suicide attempts in the YST group (17.3%) compared to the treatment as usual only group (11.6%, P=0.26).57 In the second trial, YST-II, the support team was limited to adults only and contact was only maintained for three months, which led to a slightly lower number of patients with at least one suicide attempt in the YST group (13% compared with 15%, P=0.51).56

##### Assertive Community Treatment

The Mann review did not include any RCTs of assertive community treatment.10 However, we found one RCT with unclear risk of bias that provided low-strength evidence that, compared to care from a community mental health team, assertive community treatment did not significantly reduce suicide deaths (0.8% compared with 2.5%; P not reported) or deliberate self-harm incidents (8% compared with 11%, P=0.40) over 18 months among 251 adults with serious mental illness and identified as having difficulty engaging with standard community care.58 This trial was conducted in London, and the assertive community treatment approach involved smaller case loads than carried by the community mental health teams and all team members worked with all clients, met at up to a daily frequency for discussion, used assertive contact with clients, followed a “no drop-out” policy, and offered extended hours of availability, and “in vivo” locations for appointments.

##### Case Management/Care Coordination

The Mann review10 reported fewer suicide attempts compared to control participants from one study investigating the use of a suicide intervention counselor providing care coordination/case management services; however, this information was not from an RCT and is, therefore, not included in the findings for this current report.

However, we identified a more recent secondary analysis of suicide deaths59 from the trial of older primary care patients originally included in the Mann review.120 The Prevention of Suicide in Primary Care Elderly: Collaborative Trial (PROSPECT) had unclear risk of bias and compared the effect of algorithm-based depression care management to usual care practices in 599 older primary care patients with major depression (age ≥ 60 years). PROSPECT provided low-strength evidence that algorithm-based depression care management did not significantly change the suicide mortality rate per 1,000 person-years overall (0.7 [95% CI, 0.0 to 4.2] compared with 0.0 [95% CI, 0.0 to 3.3]), or in subgroups with either major depressive disorder (N=396: 0.0 [95% CI, 0.0 to 4.1] compared with 0.0 [95% CI, 0.0 to 5.1]), or clinically significant minor depression (N=203: 2.2 [95% CI, 0.1 to 2.5] compared with 0.0 [95% CI, 0.0 to 9.7]).

##### Emergency Contact Card Interventions

The Mann review included one RCT of an emergency contact card intervention, and reported a reduced rate of suicide attempts.10 This trial provides insufficient to lowstrength evidence for the effectiveness of emergency contact interventions in preventing suicidal self-directed violence.