# REFERENCES

1 Kochanek KD, Xu J, Murphy SL, Miniño AM, Kung HC. Deaths: preliminary data for 2009. Natl Vital Stat Rep. 2011;59(4):1-51.
2 Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. National Violent Death Reporting System: Monitoring and Tracking the Causes of Violent Deaths - 2008. 2008. http://www.cdph.ca.gov/programs/Documents/nvdrs_aag_2008-a.pdf. February 29, 2012.
3 McCarthy JF, Valenstein M, Kim HM, Ilgen M, Zivin K, Blow FC. Suicide mortality among patients receiving care in the veterans health administration health system. American journal of epidemiology. Apr. 15. 2009;169(8):1033-8. [pmid: 19251753].
4 Department of Veterans Affairs. Screening and evaluation of possible traumatic brain injury in operation enduring freedom (OEF) and operation Iraqi freedom (OIF) veterans. VHA Directive 2007-013. 2007.
5 Department of Veterans Affairs. Report of the Blue Ribbon Work Group on Suicide Prevention in the Veteran Population. 2008. Available at http://www.mentalhealth.va.gov/suicide_prevention/Blue_Ribbon_Report-FINAL_June-30-08.pdf. January 3, 2012.
6 US Public Health Service. The Surgeon General's Call to Action to Prevent Suicide. Washington, D.C. 1999.
7 World Health Organization. SUPRE Prevention of suicidal behaviors: a task for all. 2007. Available at http://www.who.int/mental_health/prevention/suicide/information/en/index.html. January 3, 2012.
8 Nock MK, Borges G, Bromet EJ, Cha CB, Kessler RC, Lee S. Suicide and suicidal behavior. Epidemiol Rev. 2008;30:133-54. [pmid: 18653727].
9 Gaynes BN, West SL, Ford CA, et al. Screening for Suicide Risk in Adults: A Summary of the Evidence for the U.S. Preventive Services Task Force. Annals of Internal Medicine May. 2004;140(10):822-35.
10 Mann JJ, Apter A, Bertolote J, et al. Suicide prevention strategies: a systematic review. JAMA. Oct. 26. 2005;294(16):2064-74. [pmid: 16249421].
11 National Institute for Health and Clinical Excellence. Self-harm: longer-term management in adults, children and young people. [Draft for Consultation]. National Collaborating Centre for Mental Health. 2011.
12 Centers for Disease Control and Prevention, Crosby AE, Han B, et al. Suicidal thoughts and behaviors among adults aged ≥18 years --- United States, 2008-2009. MMWR Surveill Summ. Oct. 21. 2011;60(13):1-22. [pmid: 22012169].
13 Brenner LA, Breshears RE, Betthauser LM, et al. Implementation of a Suicide Nomenclature within Two VA Healthcare Settings. J Clin Psychol Med Settings. Jun. 2011;18(2):116-28. [pmid: 21626353].
14 Shekelle P, Bagley S, Munjas B. Strategies for Suicide Prevention in Veterans. Evidence-based Synthesis Program. 2009. Jan.
15 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. Journal of Clinical Epidemiology. 1991;44(11):1271-8. [pmid: 1834807].
16 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. Available from www.cochrane-handbook.org. 2011.
17 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
18 Emslie GJ, Wagner KD, Kutcher S, et al. Paroxetine treatment in children and adolescents with major depressive disorder: a randomized, multicenter, double-blind, placebo-controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45(6):709-19. [pmid: 16721321].
19 Emslie G, Kratochvil C, Vitiello B, et al. Treatment for Adolescents with Depression Study (TADS): safety results. J Am Acad Child Adolesc Psychiatry. Dec. 2006;45(12):1440-55. [pmid: 17135989].
20 Emslie GJ, Ventura D, Korotzer A, Tourkodimitris S. Escitalopram in the treatment of adolescent depression: A randomized placebo-controlled multisite trial. Journal of the American Academy of Child & Adolescent Psychiatry. Jul. 2009;48(7):721-9. [pmid: 19465881].
21 March JS, Silva S, Petrycki S, et al. The Treatment for Adolescents With Depression Study (TADS): long-term effectiveness and safety outcomes. Arch Gen Psychiatry. Oct. 2007;64(10):1132-43. [pmid: 17909125].
22 Wagner KD, Jonas J, Findling RL, Ventura D, Saikali K. A double-blind, randomized, placebo-controlled trial of escitalopram in the treatment of pediatric depression. J Am Acad Child Adolesc Psychiatry. Mar. 2006;45(3):280-8. [pmid: 16540812].
23 DeRubeis RJ, Hollon SD, Amsterdam JD, et al. Cognitive therapy vs medications in the treatment of moderate to severe depression. Archives of General Psychiatry. 2005;62(4):409-16. [pmid: 15809408].
24 Grunebaum MF, Ellis SP, Duan N, Burke AK, Oquendo MA, John Mann J. Pilot Randomized Clinical Trial of an SSRI vs Bupropion: Effects on Suicidal Behavior, Ideation, and Mood in Major Depression. Neuropsychopharmacology. 2011. Oct. 12.
25 Zisook S, Lesser IM, Lebowitz B, et al. Effect of antidepressant medication treatment on suicidal ideation and behavior in a randomized trial: an exploratory report from the Combining Medications to Enhance Depression Outcomes Study. J Clin Psychiatry. Oct. 2011;72(10):1322-32. [pmid: 22075098].
26 Brent DA, Emslie GJ, Clarke GN, et al. Predictors of spontaneous and systematically assessed suicidal adverse events in the treatment of SSRI-resistant depression in adolescents (TORDIA) study. Am J Psychiatry. Apr. 2009;166(4):418-26. [pmid: 19223438].
27 Goodyer IM, Dubicka B, Wilkinson P, et al. A randomised controlled trial of cognitive behaviour therapy in adolescents with major depression treated by selective serotonin reuptake inhibitors. The ADAPT trial. Health Technol Assess. May. 2008;12(14):iii-iv. ix. 60. [pmid: 18462573].
28 Calabrese J, Keck P, Macfadden W, et al. A randomized, double-blind, placebo-controlled trial of quetiapine in the treatment of Bipolar I or II depression. Am J Psychiatry. 2005;162:1351-60. [pmid: 15994719].
29 Berman RM, Marcus RN, Swanink R, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a multicenter, randomized, double-blind, placebo-controlled study. Journal of Clinical Psychiatry. 2007;68(6):843-53. [pmid: 17592907].
30 Marcus RN, McQuade RD, Carson WH, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a second multicenter, randomized, double-blind, placebo-controlled study. Journal of Clinical Psychopharmacology. 2008;28(2):156-65. [pmid: 18344725].
31 Weisler RH, Khan A, Trivedi MH, et al. Analysis of suicidality in pooled data from 2 double-blind, placebo-controlled aripiprazole adjunctive therapy trials in major depressive disorder. J Clin Psychiatry. Apr. 2011;72(4):548-55. [pmid: 20816039].
32 Oquendo M, Galfalvy H, Currier D, et al. Treatment of suicide attempters with bipolar disorder: a randomized clinical trial comparing lithium and valproate in the prevention of suicidal behavior. Am J Psychiatry. 2011;168(10):1050-6. [pmid: 21768611].
33 Khan A, Khan SR, Hobus J, et al. Differential pattern of response in mood symptoms and suicide risk measures in severely ill depressed patients assigned to citalopram with placebo or citalopram combined with lithium: Role of lithium levels. J Psychiatr Res. Nov. 2011;45(11):1489-96. [pmid: 21752394].
34 Lauterbach E, Felber W, Muller-Oerlinghausen B, et al. Adjunctive lithium treatment in the prevention of suicidal behaviour in depressive disorders: a randomised, placebo-controlled, 1-year trial. Acta Psychiatr Scand. Dec. 2008;118(6):469-79. [pmid: 18808400].
35 Hallahan B, Hibbeln JR, Davis JM, Garland MR. Omega-3 fatty acid supplementation in patients with recurrent self-harm. Single-centre double-blind randomised controlled trial. NA. 2007;190:118-22.
36 Hatcher S, Sharon C, Parag V, Collins N. Problem-solving therapy for people who present to hospital with self-harm: Zelen randomised controlled trial. Br J Psychiatry. Oct. 2011;199:310-6. [pmid: 21816868].
37 Bateman A, Fonagy P. Randomized controlled trial of outpatient mentalization-based treatment versus structured clinical management for borderline personality disorder. Am J Psychiatry. Dec. 2009;166(12):1355-64. [pmid: 19833787].
38 Linehan MM, Comtois KA, Murray AM, et al. Two-year randomized controlled trial and follow-up of dialectical behavior therapy vs therapy by experts for suicidal behaviors and borderline personality disorder. Arch Gen Psychiatry. Jul. 2006;63(7):757-66. [pmid: 16818865].
39 Blum N, St John D, Pfohl B, et al. Systems Training for Emotional Predictability and Problem Solving (STEPPS) for outpatients with borderline personality disorder: a randomized controlled trial and 1-year follow-up. [erratum appears in Am J Psychiatry 165(6): 777]. Am J Psychiatry. Apr. 2008;165(4):468-78. [pmid: 18281407].
40 Davidson K, Norrie J, Tyrer P, et al. The effectiveness of cognitive behavior therapy for borderline personality disorder: results from the borderline personality disorder study of cognitive therapy (BOSCOT) trial. J Pers Disord. Oct. 2006;20(5):450-65. [pmid: 17032158].
41 Davidson KM, Tyrer P, Norrie J, Palmer SJ, Tyrer H. Cognitive therapy v. usual treatment for borderline personality disorder: prospective 6-year follow-up. Br J Psychiatry. Dec. 2010;197:456-62. [pmid: 21119151].
42 McMain SF, Links PS, Gnam WH, et al. A randomized trial of dialectical behavior therapy versus general psychiatric management for borderline personality disorder. Am J Psychiatry. Dec. 2009;166(12):1365-74. [pmid: 19755574].
43 Winter D, Sireling L, Riley T, Metcalfe C, Quaite A, Bhandari S. A controlled trial of personal construct psychotherapy for deliberate self-harm. Psychology and Psychotherapy: Theory, Research and Practice. Mar. 2007;80(1):23-37.
44 Green JM, Wood AJ, Kerfoot MJ, et al. Group therapeutic treatment for adolescents with repeated self harm (assist) – a randomised controlled trial with economic evaluation. BMJ. 2011;342:682.
45 De Leo D, Heller T. Intensive case management in suicide attempters following discharge from inpatient psychiatric care. Australian Journal of Primary Health. 2007;13(3):49-58.
46 Diamond GS, Wintersteen MB, Brown GK, et al. Attachment-based family therapy for adolescents with suicidal ideation: A randomized controlled trial. [References]. Journal of the American Academy of Child & Adolescent Psychiatry. 2010;49(2):122-31. [pmid: 20215934].
47 Comtois KA, Jobes DA, SOC S, et al. Collaborative assessment and management of suicidality (CAMS): feasibility trial for next-day appointment services. Depress Anxiety. 2011. Sep. 21.
48 Donaldson D, Spirito A, Esposito-Smythers C. Treatment for Adolescents Following a Suicide Attempt: Results of a Pilot Trial. Journal of the American Academy of Child & Adolescent Psychiatry. Feb. 2005;44(2):113-20. [pmid: 15689724].
49 Hazell PL, Martin G, McGill K, et al. Group therapy for repeated deliberate self-harm in adolescents: failure of replication of a randomized trial. Journal of the American Academy of Child & Adolescent Psychiatry. Jun. 2009;48(6):662-70. [pmid: 19454922].
50 Stewart CD, Quinn A, Plever S, Emmerson B. Comparing cognitive behavior therapy, problem solving therapy, and treatment as usual in a high risk population. Suicide Life Threat Behav. Oct. 2009;39(5):538-47. [pmid: 19929153].
51 Tarrier N, Haddock G, Lewis S, Drake R, Gregg L, So CTG. Suicide behaviour over 18 months in recent onset schizophrenic patients: the effects of CBT. Schizophr Res. Mar. 2006;83(1):15-27. [pmid: 16460916].
52 Unutzer J, Tang L, Oishi S, et al. Reducing suicidal ideation in depressed older primary care patients. J Am Geriatr Soc. Oct. 2006;54(10):1550-6. [pmid: 17038073].
53 Beautrais AL, Gibb SJ, Faulkner A, Fergusson DM, Mulder RT. Postcard intervention for repeat self-harm: randomised controlled trial. NA. Jul. 2010;197(1):55-60.
54 Carter GL, Clover K, Whyte IM, Dawson AH, D'Este C. Postcards from the EDge project: Randomised controlled trial of an intervention using postcards to reduce repetition of hospital treated deliberate self poisoning. BMJ. Oct. 2005;331(7520):805. [pmid: 16183654].
55 Carter GL, Clover K, Whyte IM, Dawson AH, D'Este C. Postcards from the EDge: 24-month outcomes of a randomised controlled trial for hospital-treated self-poisoning. British Journal of Psychiatry. 2007;191:548-53. [pmid: 18055960].
56 King CA, Klaus N, Kramer A, Venkataraman S, Quinlan P, Gillespie B. The Youth-Nominated Support Team-Version II for suicidal adolescents: A randomized controlled intervention trial. J Consult Clin Psychol. Oct. 2009;77(5):880-93. [pmid: 19803568].
57 King CA, Kramer A, Preuss L, Kerr DC, Weisse L, Venkataraman S. Youth-Nominated Support Team for Suicidal Adolescents (Version 1): a randomized controlled trial. J Consult Clin Psychol. Feb. 2006;74(1):199-206. [pmid: 16551158].
58 Killaspy H, Bebbington P, Blizard R, et al. The REACT study: randomised evaluation of assertive community treatment in north London. BMJ. 2006;332(7545):815-20. [pmid: 16543298].
59 Gallo JJ, Bogner HR, Morales KH, Post EP, Lin JY, Bruce ML. The effect of a primary care practice-based depression intervention on mortality in older adults: a randomized trial. [Summary for patients in Ann Intern Med. 2007 May 15;146(10):I38; PMID: 17502628]. Annals of Internal Medicine. 2007;146(10):689-98. [pmid: 17502629].
60 Centers for Disease Control and Prevention (CDC). Suicide facts at a glance. National Center for Injury Prevention and Control. 2009. Available at http://www.cdc.gov/violenceprevention/pdf/Suicide-DataSheet-a.pdf. 1/3/2012.
61 Goldsmith SK, Pelmar TC, Kleinman AM, Bunny WE, editors. Reducing suicide: A national imperative. Washington (DC). National Academy Press. 2002.
62 Jordan JR. Is suicide bereavement different? A reassessment of the literature. Suicide Life Threat Behav. 2001;31(1):91-102. [pmid: 11326773].
63 Corso PS, Mercy JA, Simon TR, Finkelstein EA, Miller TR. Medical costs and productivity losses due to interpersonal and self-directed violence in the United States. Am J Prev Med. Jun. 2007;32(6):474-82. [pmid: 17533062].
64 Lambert MT. Seven-year outcomes of patients evaluated for suicidality. Psychiatr Serv. 2002;53(1):92-4. [pmid: 11773656].
65 Lambert MT, Fowler DR. Suicide risk factors among veterans: risk management in the changing culture of the Department of Veterans Affairs. J Ment Health Adm. 1997;24(3):350-8. [pmid: 9230576].
66 Martin J, Ghahramanlou-Holloway M, Lou K, Tucciarone P. A comparative review of U.S. Military and civilian suicide behavior: Implications for OEF/OIF suicide prevention efforts. Journal of Mental Health and Counseling. 2009;31(2):101-18.
67 Schulberg HC, Bruce ML, Lee PW, Williams JW J, Dietrich AJ. Preventing suicide in primary care patients: the primary care physician's role. Gen Hosp Psychiatry. 2004;26(5):337-45. [pmid: 15474633].
68 Teasdale T, Engberg A. Suicide after traumatic brain injury: a population study. Journal of Neurology, Neurosurgery & Psychiatry. 2001;71(4):436-40.
69 Joiner T. Why people die by suicide. Cambridge. Harvard University Press. 2005.
70 Brenner LA, Gutierrez PM, Cornette MM, Betthauser LM, Bahraini N, Staves PJ. A Qualitative study of potential suicide risk factors in returning combat veterans. Journal of Mental Health Counseling. Jul. 2008;30(3):211-25.
71 Cavanagh J, Carson A, Sharpe M, SM L. Psychological autopsy studies of suicide: A systematic review. Psychological Medicine. 2003;33:395-405. [pmid: 12701661].
72 Luoma J, Martin C, Pearson J. Contact with mental health and primary care providers before suicide: A review of the evidence. American Journal of Psychiatry. 2002;159(6):909-16. [pmid: 12042175].
73 Basham C, Denneson LM, Millet L, Shen X, Duckart J, Dobscha SK. Characteristics and VA Health Care Utilization of U. S. Veterans Who Completed Suicide in Oregon Between 2000 and 2005. Suicide Life Threat Behav. Apr. 4. 2011;42(3):287-96. [pmid: 21463353].
74 Department of Veterans Affairs. 2001 National Survey of Veterans. 2001. Available at http://www.va.gov/VETDATA/docs/SurveysAndStudies/NSV_Final_Report.pdf. January 3, 2012.
75 Brown GK, Ten Have T, Henriques GR, Xie SX, Hollander JE, Beck AT. Cognitive therapy for the prevention of suicide attempts: a randomized controlled trial. JAMA. Aug. 3. 2005;294(5):563-70. [pmid: 16077050].
76 Crawford MJ, Thomas O, Khan N, Kulinskaya E. Psychosocial interventions following self-harm: systematic review of their efficacy in preventing suicide. Br J Psychiatry. Jan. 2007;190:11-7. [pmid: 17197651].
77 Motto JA, Bostrom AG. A randomized controlled trial of postcrisis suicide prevention. Psychiatr Serv. 2001;52(6):828-33. [pmid: 11376235].
78 Paris J. Predicting and Preventing Suicide: Do We Know Enough to Do Either?. Harvard Review of Psychiatry. Sep-Oct. 2006;14(5):233-40. [pmid: 16990168].
79 Moher D, Liberati A, Tetzlaff J, Altman DG, The Prisma Group. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
80 Asenjo Lobos C, Komossa K, Rummel-Kluge C, et al. Clozapine versus other atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2010;(11):CD006633. [pmid: 21069690].
81 Barbui C, Furukawa TA, Cipriani A. Effectiveness of paroxetine in the treatment of acute major depression in adults: a systematic re-examination of published and unpublished data from randomized trials. Canadian Medical Association Journal. 2008;178(3):296-305. [pmid: 18227449].
82 Barbui C, Esposito E, Cipriani A. Selective serotonin reuptake inhibitors and risk of suicide: a systematic review of observational studies. CMAJ. Feb. 3. 2009;180(3):291-7. [pmid: 19188627].
83 Cipriani A, Brambilla P, Furukawa T, et al. Fluoxetine versus other types of pharmacotherapy for depression. Cochrane Database Syst Rev. 2005;(4):CD004185. [pmid: 16235353].
84 Cipriani A, Pretty H, Hawton K, Geddes JR. Lithium in the prevention of suicidal behavior and all-cause mortality in patients with mood disorders: a systematic review of randomized trials. Am J Psychiatry. Oct. 2005;162(10):1805-19. [pmid: 16199826].
85 Cipriani A, Smith KA, Burgess SSA, Carney SM, Goodwin G, Geddes J. Lithium versus antidepressants in the long-term treatment of unipolar affective disorder. Cochrane Database of Systematic Reviews. 2009;(1).
86 Craig M, Howard L. Postnatal depression. Clin Evid (Online). 2009:2009.
87 Dubicka B, Elvins R, Roberts C, Chick G, Wilkinson P, Goodyer IM. Combined treatment with cognitive-behavioural therapy in adolescent depression: meta-analysis. Br J Psychiatry. Dec. 2010;197:433-40. [pmid: 21119148].
88 Grandjean EM, Aubry JM. Lithium: updated human knowledge using an evidence-based approach: Part I: Clinical efficacy in bipolar disorder. CNS Drugs. 2009;23(3):225-40. [pmid: 19320531].
89 Hazell P. Depression in children and adolescents. Clin Evid (Online). 2011:2011.
90 Innamorati M, Pompili M, Amore M, et al. Suicide prevention in late life: Is there sound evidence for practice?. Pompili M, Tatarelli R, editors. Evidence-based practice in suicidology: A source book. Cambridge, MA. Hogrefe Publishing. 2011:211-32.
91 Hammerness PG, Vivas FM, Geller DA. Selective serotonin reuptake inhibitors in pediatric psychopharmacology: a review of the evidence. J Pediatr. Feb. 2006;148(2):158-65. [pmid: 16492422].
92 McDonagh M, Peterson K, Carson S, Fu R, Thakurta S. Drug Class Review: Atypical Antipsychotic Drugs: Final Update 3 Report. Drug Effectiveness Review Project. 2010. Jul. Oregon Health and Science University.
93 Robinson J, Hetrick SE, Martin C. Preventing suicide in young people: systematic review. Aust N Z J Psychiatry. Jan. 2011;45(1):3-26. [pmid: 21174502].
94 Sakinofsky I. Treating suicidality in depressive illness. Part 2: does treatment cure or cause suicidality?. Can J Psychiatry. Jun. 2007;52(6 Suppl 1):85S-101S. [pmid: 17824355].
95 Sakinofsky I. Treating suicidality in depressive illness. Part 1: current controversies. Can J Psychiatry. Jun. 2007;52(6 Suppl 1):71S-84S. [pmid: 17824354].
96 Soomro GM. Deliberate self-harm (and attempted suicide). Clin Evid (Online). 2008;12:1012.
97 Van Lieshout RJ, MacQueen GM. Efficacy and acceptability of mood stabilisers in the treatment of acute bipolar depression: systematic review. Br J Psychiatry. Apr. 2010;196:266-73. [pmid: 20357301].
98 Williams SB, O'Connor E, Eder M, Whitlock E. Screening for Child and Adolescent Depression In Primary Care Settings: A Systematic Evidence Review for the U.S. Preventive Services Task Force. 2009. Apr.
99 Williams SB, O'Connor EA, Eder M, Whitlock EP. Screening for child and adolescent depression in primary care settings: a systematic evidence review for the US Preventive Services Task Force. Pediatrics. Apr. 2009;123(4):e716-35. [pmid: 19336361].
100 National Collaborating Centre for Mental Health. Depression in children and young people: identification and management in primary, community and secondary care. British Psychological Society. 2005:233.
101 Ziemba KS, O'Carroll CB, Drazkowski JF, et al. Do antiepileptic drugs increase the risk of suicidality in adult patients with epilepsy?: a critically appraised topic. Neurologist. Sep. 2010;16(5):325-8. [pmid: 20827125].
102 Abbass AA, Hancock JT, Henderson J, Kisely SR. Short-term psychodynamic psychotherapies for common mental disorders. Cochrane Database of Systematic Reviews. 2009;(1).
103 Bagley SC, Munjas B, Shekelle P. A systematic review of suicide prevention programs for military or veterans. Suicide Life Threat Behav. Jun. 2010;40(3):257-65. [pmid: 20560747].
104 Binks C, Fenton M, McCarthy L, Lee T, Adams CE, Duggan C. Psychological therapies for people with borderline personality disorder. Cochrane Database of Systematic Reviews. 2011;(1).
105 Corcoran J, Dattalo P, Crowley M, Brown E, Grindle L. A systematic review of psychosocial interventions for suicidal adolescents. Children and Youth Services Review. Nov. 2011;33(11):2112-8.
106 Dieterich M, Irving CB, Park B, Marshall M. Intensive case management for severe mental illness. Cochrane Database Syst Rev. 2010;(10):CD007906. [pmid: 20927766].
107 Irving CB, Adams CE, Rice K. Crisis intervention for people with severe mental illnesses. Cochrane Database of Systematic Reviews. 2010;(5).
108 Kavanagh J, Oliver S, Caird J, et al. Inequalities and the mental health of young people: a systematic review of secondary school-based cognitive behavioural interventions. (Structured abstract). University of London, Institute of Education, Social Science Research Unit, EPPI-Centre. 2009:1-109.
109 Lapierre S, Erlangsen A, Waern M, et al. A systematic review of elderly suicide prevention programs. Crisis. Jan. 1. 2011;32(2):88-98. [pmid: 21602163].
110 Leenaars AA. Evidence-based psychotherapy with suicidal people: A systematic review. Pompili Maurizio, editor. 2011:89-123.
111 Muralidharan S, Fenton M. Containment strategies for people with serious mental illness. Cochrane Database of Systematic Reviews. 2009;(1).
112 Newton AS, Hamm MP, Bethell J, et al. Pediatric suicide-related presentations: a systematic review of mental health care in the emergency department. Ann Emerg Med. Dec. 2010;56(6):649-59. [pmid: 20381916].
113 Pharoah F, Mari J, Rathbone J, Wong W. Family intervention for schizophrenia. Cochrane Database Syst Rev. 2010;(12):CD000088. [pmid: 21154340].
114 Shek E, Stein AT, Shansis FM, Marshall M, Crowther R, Tyrer P. Day hospital versus outpatient care for people with schizophrenia. Cochrane Database of Systematic Reviews. 2010;(11).
115 State of Victoria Department of Health. Suicide risk assessment and management: A systematic evidence review for the Clinical practice guidelines for emergency departments and mental health services project. Mental Health, Drugs and Regions Division. 2010.
116 Takada M, Shima S. Characteristics and effects of suicide prevention programs: comparison between workplace and other settings. Ind Health. 2010;48(4):416-26. [pmid: 20720333].
117 Bateman A, Fonagy P. 8-year follow-up of patients treated for borderline personality disorder: mentalization-based treatment versus treatment as usual. The American Journal of Psychiatry. May. 2008;165(5):631-8. [pmid: 18347003].
118 Hailey D, Roine R, Ohinmaa A. The effectiveness of telemental health applications: A review. The Canadian Journal of Psychiatry / La Revue canadienne de psychiatrie. Nov. 2008;53(11):769-78.
119 van der Feltz-Cornelis CM, Sarchiapone M, Postuvan V, et al. Best Practice Elements of Multilevel Suicide Prevention Strategies. Crisis. Sep. 2011;26:1-15.
120 Bruce M, Ten Have T, Reynolds CI, et al. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. 2004;291(9):1081-91. [pmid: 14996777].
121 Wortzel HS, Gutierrez PM, Homaifar BY, Breshears RE, Harwood JE. Surrogate endpoints in suicide research. Suicide Life Threat Behav. Oct. 2010;40(5):500-5. [pmid: 21034212].
122 Wasserman D, Wasserman C, editors. Oxford Textbook of Suicidology and Suicide Prevention: A Global Perspective. New York. Oxford University Press. 2009.
123 Shekelle P, Woolf S, Eccles M, Grimshaw J. Clinical guidelines: Developing guidelines. British Medical Journal. 1999;318(7183):593-6. [pmid: 10037645].
124 Vitiello B, Silva SG, Rohde P, et al. Suicidal events in the Treatment for Adolescents With Depression Study (TADS). J Clin Psychiatry. May. 2009;70(5):741-7. [pmid: 19552869].
125 March J, Silva S, Vitiello B, Team T. The Treatment for Adolescents with Depression Study (TADS): methods and message at 12 weeks. Journal of the American Academy of Child and Adolescent Psychiatry. Dec. 2006;45(12):1393-403. [pmid: 17135984].
126 Brent D, Emslie G, Clarke G, et al. Switching to another SSRI or to venlafaxine with or without cognitive behavioral therapy for adolescents with SSRI-resistant depression: the TORDIA randomized controlled trial. JAMA. 2008;299(8):901-13. [pmid: 18314433].
127 Schulberg HC, Bryce C, Chism K, et al. Managing late-life depression in primary care practice: a case study of the Health Specialist's role. International Journal of Geriatric Psychiatry. 2001;16(6):577-84. [pmid: 11424166].
128 Bogner HR, Morales KH, Post EP, Bruce ML. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT). Diabetes Care. Dec. 2007;30(12):3005-10. [pmid: 17717284].
129 Raue PJ, Morales KH, Post EP, Bogner HR, Have TT, Bruce ML. The wish to die and 5-year mortality in elderly primary care patients. Am J Geriatr Psychiatry. Apr. 2010;18(4):341-50. [pmid: 19910882].