# METHODS

## TOPIC DEVELOPMENT

This project was requested by the VA/Department of Defense (DoD) Evidence Based Practice Working Group (EBPWG) to support the development of clinical practice guidelines for suicide prevention. The VA/DoD suicide prevention EBPWG requested a systematic review of literature related to suicidal self-directed violence as defined by Crosby et al. and Brenner et al.12, 13 published since two prior reports on the topic by Mann et al. and Gaynes et al.9, 10 The workgroup requested a review which was focused on countries and populations of interest due to their similarity to US Veteran and military populations. Though a similar report on self-harm recently conducted by the National Institute for Health and Clinical Excellence (NICE) was released in draft form during the writing of this current report,11 the EBPWG requested this current ESP report to examine suicidal self-directed violence, specifically, rather than self-harm in general, and to focus on populations most comparable to US Veterans and members of the military. A technical panel comprised of members of this workgroup as well as VA leaders in the field of suicidology provided input.

The final key questions developed a priori in conjunction with the EBPWG are:

Key Question #1 What is the effectiveness of specific interventions for reducing rates of suicidal self-directed violence in military and/or Veteran populations?
Key Question #2 What lessons can be learned from suicidal self-directed violence prevention intervention research conducted outside of Veteran or military settings that can be applied to Veteran and/or military populations?
Key Question #3 What is the effectiveness of referral and follow-up services (e.g., strategies designed to provide referrals, improve referral follow-through and attendance, etc.) for reducing rates of suicidal self-directed violence in military and/or Veteran populations?
Key Question #4 What lessons can be learned from research on suicidal self-directed violence referral and follow-up services conducted outside of Veteran or military settings that can be applied to Veteran and/or military populations?

## SEARCH STRATEGY

The VA/DoD suicide prevention EBPWG workgroup requested a systematic review of literature related to suicidal self-directed violence published since two prior reports on the topic by Mann et al. and Gaynes et al.9, 10 The workgroup requested a review which was focused on countries and populations of interest due to their similarity to US Veteran and military populations. Though a previous systematic review was conducted by Shekelle and colleagues in 2009,^14^ the EBPWG requested that the current review include studies of pharmacotherapy and psychotherapy interventions, which were largely excluded from this previous report; and, therefore, we used the end search date from the Mann et al. review as the starting point for the current search. To identify relevant systematic reviews and controlled trials, we searched PubMed, PsycINFO, the Cochrane Database of Systematic Reviews^®^, and the Cochrane Central Register of Controlled Trials^®^. Our search focused on identifying all new studies published since the systematic reviews completed by Mann et al. in 2005 and Gaynes et al. in 2004,^9, 10^ and covered the period from January 2005 to November 18, 2011. Therefore, we used a similar search strategy including suicide and all related terms; we also included interventions and military and Veteran populations as search terms (Appendix A). We limited the search to peer-reviewed articles involving human subjects and published in the English language that were not included in previously published systematic reviews on the topic.9, 10

To assure that our search did not miss relevant articles on suicidal self-directed violence interventions, we obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and consulting experts. Additionally, though the focus of the requested review was on interventions and services to reduce suicide, we included any intervention reporting on suicidal self-directed violence as an outcome to include as comprehensive a list of articles as possible with the potential for suicidal self-directed violence prevention efficacy.

## STUDY SELECTION

Titles and abstracts were reviewed by doctoral level investigators and project research associates trained in the critical analysis of literature. Eligibility of full-text articles was initially carefully ascertained by one reviewer and the accuracy of all assessments was then checked by a second reviewer. All disagreements were resolved by consensus.

To determine the evidence base for interventions and referral/follow-up services to prevent suicide in Veteran and military populations, we examined randomized controlled trials (RCTs) of interventions and referral/follow-up services that can be implemented at an individual level for a person identified as being at risk for suicide. Though observational studies and studies lacking a control or comparison condition can provide important information about the natural course of suicide, the focus of this report was on RCTs in an attempt to examine the highest quality evidence with the least potential for biased results.

Our review was designed to detect the highest quality evidence evaluating individual-level interventions and study settings/populations that most closely approximate US Veteran and military populations. Therefore, though we used selection criteria similar to those used in the reviews by Mann et al. and Gaynes et al., our review differs from these reviews in: 1) excluding observational studies, 2) excluding trials of community-based interventions, and 3) excluding trials conducted in countries dissimilar to the US.

We classified studies as pharmacotherapy interventions, psychotherapy interventions, or referral and follow-up services. We defined interventions as treatments designed to impact a condition, symptom, or behavior. Referral and follow-up services were any services that were provided to patients that were primarily designed to facilitate access to interventions rather than treat a condition, symptom, or behavior. Because many interventions include components designed to increase adherence and attendance, we classified any study describing an intervention component as an “intervention” study rather than a “referral and follow-up services” study even if it also included components of referral and follow-up services. Therefore, the studies designated as referral and follow-up services were described by the authors as solely designed to increase access to, attendance at, and/or adherence to other interventions not included in the study design.

Below are listed the specific inclusion criteria used to select studies for each Key Question, respectively:

Key Question #1 Primary literature review of studies published between 2005 and November 18, 2011, with the following characteristics:
  - Population: Any Veteran and/or military patient subgroup from the US, United Kingdom (UK), Canada, New Zealand, and Australia.
  - Intervention: Any intervention with the potential to reduce or prevent suicidal selfdirected violence including interventions related to environmental modification, psychotherapy, medication, somatic treatment, and monitoring. This report will include individual-level interventions applicable to clinical encounter settings (i.e., services that can be provided to individual patients). This report will exclude more broadly focused population-level or public health types of interventions designed to be implemented with large groups of people with unknown individual suicide risk levels.
  - Comparator: No intention to limit by comparator.
  - Outcomes: Suicidal self-directed violence including suicide attempt and suicide, not including self-directed violence ideation and undetermined or non-suicidal self-directed violence (i.e., behavior resulting in injury for which there is unclear or no implicit or explicit evidence of intent to die).
  - Timing: Any length of follow-up.
  - Setting: US Veteran or military inpatient or outpatient settings.
Key Question #2 Review of suicidal self-directed violence prevention intervention research conducted in non-Veteran and/or non-military settings with the same parameters as Key Question #1 other than population.
Key Question #3 Primary literature review of studies published between 2005 and November 18, 2011, with the following characteristics:
  - Population: Any Veteran and/or military patient subgroup from the US, UK, Canada, New Zealand, and Australia.
  - Intervention: Any referral or follow-up service with the potential to reduce or prevent suicidal self-directed violence including referral/follow-up services related to care coordination, provider contact, and social support. This report will include individuallevel referral/follow-up services applicable to clinical encounter settings (i.e., services that can be provided to individual patients). This report will exclude more broadly focused population-level or public health types of referral/follow-up services designed to be implemented with large groups of people with unknown individual suicide risk levels.
  - Comparator: No intention to limit by comparator.
  - Outcomes: Suicidal self-directed violence including suicide attempt and suicide, not including self-directed violence ideation and undetermined or non-suicidal self-directed violence (i.e., behavior resulting in injury for which there is unclear or no implicit or explicit evidence of intent to die).
  - Timing: Any length of follow-up.
  - Setting: Any non-Veteran or non-military inpatient or outpatient setting.
Key Question #4 Review of suicidal self-directed violence referral and follow-up services research conducted in non-Veteran and/or non-military settings with the same parameters as Key Question #3 other than population.

The complete study selection form including abstract and full-text codes is included in Appendix B.

## DATA ABSTRACTION

For controlled trials, we abstracted information on setting, population characteristics, interventions, comparators, number of subjects, length of follow-up, outcome assessment methods, and results. For systematic reviews, we abstracted information on time period and databases searched and eligibility criteria used; and for all included studies that also met our eligibility criteria, we also abstracted information on study designs, setting, sample size, population characteristics, interventions and comparators, and main results.

## QUALITY ASSESSMENT

We assessed the quality of systematic reviews using predefined criteria established by Oxman and Guyatt in 1991.^15^ The Oxman and Guyatt quality rating system consists of nine questions that involve assessing the adequacy of systematic review methods including searching, reporting of inclusion criteria, study selection, validity assessment, data synthesis, and conclusions. Each question is scored as ‘Yes,’ ‘Partially/Can't Tell,’ or ‘No’. The overall quality is scored based on a scale of 1 to 7, where 1 represents the presence of extensive flaws and 7 represents the presence of minimal flaws (Appendix C).

We assessed the risk of bias of controlled trials using the tool described in version 5.1.0 of the Cochrane Handbook for Systematic Reviews of Interventions.16 The Cochrane Collaboration's tool for assessing risk of bias involves assessing the adequacy of the following six domains: sequence generation, allocation concealment, blinding of participants, personnel and outcome assessors, handling of incomplete data, selective outcome reporting, and any other sources of bias. Adequacy for each domain is rated as ‘yes,’ ‘no,’ or ‘unclear’. The overall risk of bias for each controlled trial is then rated as ‘low,’ ‘unclear,’ or ‘high’ based on the reviewer's judgment of the plausibility that the biases have seriously weakened their confidence in the results (Appendix D).

Two reviewers independently assessed the quality of each study. Reviewers then compared their ratings and resolved all differences through discussion or by consulting a third party when consensus could not be reached.

We assessed studies for applicability to US Veterans and members of the US Armed Forces, and included a qualitative assessment of applicability to these populations of interest in the discussion section of this report.

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by key question, intervention, or clinical condition, as appropriate. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each key question or clinical topic, and drew conclusions based on qualitative synthesis of the findings.

We also report findings as described in the prior systematic review by Mann et al. Because our review was designed to be an update to the report by Mann et al., we have not re-evaluated the source studies included in their report.

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for outcomes based on the guidance established for the Evidence-based Practice Center (EPC) Program of the Agency for Healthcare Research and Quality (AHRQ) (Appendix E).17 The AHRQ EPC approach requires assessment of four key domains: risk of bias, consistency, directness, and precision. When relevant, reviewers may also consider the following additional optional domains: dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias. Ratings across the multiple domains are then combined to formulate a global assessment of the overall strength of the evidence. The strength of the evidence level is rated as ‘high,’ ‘moderate,’ ‘low,’ or ‘insufficient’ based on the reviewers' confidence that the evidence reflects the true effect and their judgment about the likelihood that further research will change the estimate.

Our review was designed only to examine studies published since June, 2005, so we consider the findings from the Mann et al. review to assess the contributions of pre-2005 literature on the overall strength of evidence. However, because Mann et al. used different quality assessment and data synthesis methodology, the combination of results from the two reports should be interpreted with caution.

To provide a summary of evidence combining the results of the Mann et al. and our reviews, we report all positive findings from the Mann et al. review along with results from the studies included in our review. We did not present negative findings from the Mann et al. report because it was impossible to discern whether these results represented a lack of good quality evidence or a true negative result. Acknowledging the limitations in combining studies from two reviews in this way, we have clearly identified those studies from the Mann review separately from the newer studies included in our review.

## PEER REVIEW

A draft version of this report was reviewed by eight technical experts, as well as clinical leadership. Their comments and our responses are presented in Appendix AA.