# CRITERIA USED TO ASSESS STRENGTH OF EVIDENCE17

Definitions of the Grades of Overall Strength of Evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Domains Used to Grade the Strength of Evidence

Domain | Definition and Elements | Score and Application
Risk of bias | Risk of bias is the degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design (e.g., RCTs or observational studies); - Aggregate quality of the studies under consideration. Information for this determination comes from the rating of quality (good/fair/poor) done for individual studies. | Use one of the three levels of aggregate risk of bias:; - Low risk of bias; - Medium risk of bias; - High risk of bias
Consistency | The principle definition of consistency is the degree to which reported effect sizes from included studies appear to have the same direction of effect. This can be assessed through two main elements:; - Effect sizes have the same sign (that is, are on the same side of “no effect”).; - The range of effect sizes is narrow. | Use one of the three levels of consistency:; - Consistent (i.e., no inconsistency); - Inconsistent; - Unknown or not applicable (e.g., single study); As noted in the text, single-study evidence bases (even mega trials) cannot be judged with respect to consistency. In that instance, use “Consistency unknown (single study)”.
Directness | The rating of directness relates to whether the evidence links the interventions directly to health outcomes. For a comparison of two treatments, directness implies that head-to-head trials measure the most important health or ultimate outcomes. Two types of indirectness, which can coexist, may be of concern. Evidence is indirect if:; - It uses intermediate or surrogate outcomes instead of ultimate health outcomes. In this case, one body of evidence links the intervention to intermediate outcomes and another body of evidence links the intermediate to most important (health or ultimate) outcomes.; - It uses two or more bodies of evidence to compare interventions A and B – e.g., studies of A vs. placebo and B vs. placebo, or studies of A vs. C and B vs. C but not A vs. B.; Indirectness always implies that more than one body of evidence is required to link interventions to the most important health outcomes.; Directness may be contingent on the outcomes of interest. EPC authors are expected to make clear the outcomes involved when assessing this domain. | Score dichotomously as one of two levels directness:; - Direct; - Indirect; If indirect, specify which of the two types of indirectness accounts for the rating (or both if that is the case) – namely, use of intermediate/ surrogate outcomes rather than health outcomes, and use of indirect comparisons. Comment on the potential weaknesses caused by, or inherent in, the indirect analysis. The EPC should note if both direct and indirect evidence was available, particularly when indirect evidence supports a small body of direct evidence.
Precision | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome (i.e., for each outcome separately). If a meta-analysis was performed, this will be the CI around the summary effect size. | Score dichotomously as one of two levels of precision:; - Precise; - Imprecise; A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the CI is wide enough to include clinically distinct conclusions. For example, results may be statistically compatible with both clinically important superiority and inferiority (i.e., the direction of effect is unknown), a circumstance that will preclude a valid conclusion.
Strength of association (magnitude of effect) | Strength of association refers to the likelihood that the observed effect is large enough that it cannot have occurred solely as a result of bias from potential confounding factors. | This additional domain should be considered if the effect size is particularly large. Use one of two levels:; - Strong: large effect size that is unlikely to have occurred in the absence of a true effect of the intervention.; - Weak: small enough effect size that it could have occurred solely as a result of bias from confounding factors.