# EXCLUDED STUDIES

The following full-text publications were considered for inclusion but failed to meet the criteria for this report.

Exclusion codes:

- 1 = non-English language
- 2 = ineligible country
- 3 = ineligible outcome
- 4 = ineligible intervention
- 5 = did not evaluate interventions
- 6 = ineligible publication type
- 7 = ineligible systematic review due to limitations in quality
- 8 = ineligible nonsystematic regulatory agency analysis
- 9 = ineligible design

Excluded Trials | | Exclusion Code
1 | Agius M, Gardner J, Liu K, Zaman R. An audit to compare discharge rates and suicidality between antidepressant monotherapies prescribed for unipolar depression. Psychiatria Danubina. 2010;22(2):350-3. | 3
2 | Agius M, Shah S, Ramkisson R Murphy S, Zaman R. Three year outcomes of an early intervention for psychosis service as compared with treatment as usual for first psychotic episodes in a standard community mental health team - final results. Psychiatr Danub. 2007 Sep;19(3):130-8. | 9
3 | Agomelatine: new drug. Adverse effects and no proven efficacy. Prescrire Int. 2009 Dec;18(104):241-5. | 6
4 | Aksoy-Poyraz C, Ozdemir A, Ozmen M, Arikan K, Ozkara C. Electroconvulsive therapy for bipolar depressive and mixed episode with high suicide risk after epilepsy surgery. Epilepsy & Behavior. 2008 Nov;13(4):707-9. | 2
5 | Alexander MJ, Haugland G, Ashenden P, Knight E, Brown I. Coping with thoughts of suicide: techniques used by consumers of mental health services. Psychiatr Serv. 2009 Sep;60(9):1214-21. | 5
6 | Alexopoulos GS, Katz IR, Bruce ML, et al. Remission in Depressed Geriatric Primary Care Patients: A Report From the PROSPECT Study. The American Journal of Psychiatry. 2005 Apr;162(4):718-24. | 3
7 | Andersson N, Ledogar RJ. The CIET Aboriginal Youth Resilience Studies: 14 Years of Capacity Building and Methods Development in Canada. Pimatisiwin. 2008 Summer;6(2):65-88. | 6
8 | Andrade C, Bhakta SG, Singh NM. Controversy revisited: Selective serotonin reuptake inhibitors in paediatric depression. World J Biol Psychiatry. 2006;7(4):251-60. | 6
9 | Angst J, Angst F, Gerber-Werder R, Gamma A. Suicide in 406 Mood-Disorder Patients With and Without Long-Term Medication: A 40 to 44 Years' Follow-Up. Archives of Suicide Research. 2005 Sep;9(3):279-300. | 2
10 | Apter A, Lipschitz A, Fong R, et al. Evaluation of suicidal thoughts and behaviors in children and adolescents taking paroxetine. J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(l-2):77-90. | 6
11 | Arkov K, Rosenbaum B, Christiansen L, Jonsson H, Munchow M. [Treatment of suicidal patients: The Collaborative Assessment and Management of Suicidality]. Ugeskr Laeger. 2008 Jan 14;170(3):149-53. | 1
12 | Army Suicide Prevention Task Force. Army Health Promotion, Risk Reduction and Suicide Prevention: Report 2010. Washington, D.C.: Department of Defense; 2010. | 6
13 | Arnevik E, Wilberg T, Urnes O, Johansen M, Monsen JT, Karterud S. Psychotherapy for personality disorders: short-term day hospital psychotherapy versus outpatient individual therapy - a randomized controlled study. Eur Psychiatry. 2009 Mar;24(2):71-8. | 2
14 | Asarnow JR, Porta G, Spirito A, et al. Suicide attempts and nonsuicidal self-injury in the treatment of resistant depression in adolescents: findings from the TORDIA study. J Am Acad Child Adolesc Psychiatry. 2011 Aug;50(8):772-81. | 6
15 | Aseltine RH, Jr., James A, Schilling EA, Glanovsky J. Evaluating the SOS suicide prevention program: a replication and extension. BMC Public Health. 2007;7:161. | 9
16 | Baber K, Bean G. Frameworks: A community-based approach to preventing youth suicide. Journal of Community Psychology. 2009 Aug;37(6):684-96. | 3
17 | Bajbouj M, Merkl A, Schlaepfer TE, et al. Two-year outcome of vagus nerve stimulation in treatment-resistant depression. J Clin Psychopharmacol. 2010 Jun;30(3):273-81. | 2
18 | Bakim B, Karamustafalioglu K, Akpinar A. Suicides and attempted suicides in alcohol and other substance use disorders. Bagimlik Dergisi. 2007 Aug;8(2):91-6. | 1
19 | Bakim B, Karamustafalioglu K, Ogutcen O, Yumrukcal H. Alcohol-Substance Use Disorders in HIV Infection. Bagimlik Dergisi. 2006 Aug;7(2):91-7. | 1
20 | Baldessarini RJ, Pompili M, Tondo L. Suicidal risk in antidepressant drug trials. Arch Gen Psychiatry. 2006 Mar;63(3):246-8. | 6
21 | Baldessarini RJ, Tondo L, Davis P, Pompili M, Goodwin FK, Hennen J. Decreased risk of suicides and attempts during long-term lithium treatment: a meta-analytic review. Bipolar Disord. 2006 Oct;8(5 Pt 2):625-39. | 7
22 | Baldwin DS, Reines EH, Guiton C, Weiller E. Escitalopram therapy for major depression and anxiety disorders. Ann Pharmacother. 2007 Oct;41(10):1583-92. | 6
23 | Balis T, Postolache TT. Ethnic differences in adolescent suicide in the United States. International Journal of Child Health and Human Development. 2008;1(3,Spec Iss):281-96. | 6
24 | Ballard ED, Pao M, Horowitz L, Lee LM, Henderson DK, Rosenstein DL. Aftermath of suicide in the hospital: institutional response. Psychosomatics. 2008 Nov-Dec;49(6):461-9. | 6
25 | Banerjee S, Hellier J, Dewey M, et al. Sertraline or mirtazapine for depression in dementia (HTA-SADD): a randomised, multicentre, double-blind, placebo-controlled trial. Lancet. 2011 Jul 30;378(9789):403-11. | 3
26 | Bangs ME, Tauscher-Wisniewski S, Polzer J, et al. Meta-analysis of suicide-related behavior events in patients treated with atomoxetine. Journal of the American Academy of Child & Adolescent Psychiatry. 2008 Feb;47(2):209-18. | 6
27 | Barak A. Emotional support and suicide prevention through the Internet: A field project report. Computers in Human Behavior. 2007 Mar;23(2):971-84. | 2
28 | Barak Y, Olmer A, Aizenberg D. Antidepressants reduce the risk of suicide among elderly depressed patients. Neuropsychopharmacology. 2006 Jan;31(1): 178-81. | 9
29 | Barbe RP, Rubovszky G, Venturini-Andreoli A, Andreoli A. The treatment of borderline personality disorder patients with current suicidal behaviour. Clinical Neuropsychiatry: Journal of Treatment Evaluation. 2005 Sep;2(5):283-91. | 6
30 | Bartlett ML. The efficacy of no-suicide contracts with clients in counseling on an outpatient basis. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2006;67(6-B):3438. | 3
31 | Basham C, Denneson LM, Millet L, Shen X, Duckart J, Dobscha SK. Characteristics and VA Health Care Utilization of U. S. Veterans Who Completed Suicide in Oregon Between 2000 and 2005. Suicide Life Threat Behav. 2011 Apr 4;42(3):287-96. | 9
32 | Bauer MS, Wisniewski SR, Kogan JN, Marangell LB, Thase ME, Sachs G. Brief report: paroxetine in younger and adult individuals at high risk for suicide. Psychopharmacol Bull. 2006;39(1):31-7. | 3
33 | Beasley CM, Jr., Ball SG, Nilsson ME, et al. Fluoxetine and adult suicidality revisited: an updated meta-analysis using expanded data sources from placebo-controlled trials. J Clin Psychopharmacol. 2007 Dec;27(6):682-6. | 8
34 | Beautrais A, Fergusson D, Coggan C, et al. Effective strategies for suicide prevention in New Zealand: a review of the evidence. N Z Med J. 2007; 120(1251):U2459. | 6
35 | Beautrais AL, Fergusson DM, Horwood LJ. Firearms legislation and reductions in firearm-related suicide deaths in New Zealand. Aust N Z J Psychiatry. 2006 Mar;40(3):253-9. | 4
36 | Beautrais AL, Gibb SJ, Fergusson DM, Horwood LJ, Larkin GL. Removing bridge barriers stimulates suicides: an unfortunate natural experiment. Aust N Z J Psychiatry. 2009 Jun;43(6):495-7. | 4
37 | Bennewith O, Nowers M, Gunnell D. Effect of barriers on the Clifton suspension bridge, England, on local patterns of suicide: implications for prevention. Br J Psychiatry. 2007 Mar;190:266-7. | 4
38 | Berard R, Fong R, Carpenter DJ, Thomason C, Wilkinson C. An international, multicenter, placebo-controlled trial of paroxetine in adolescents with major depressive disorder. J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(1-2):59-75. | 2
39 | Bergen H, Hawton K, Murphy E, et al. Trends in prescribing and self-poisoning in relation to UK regulatory authority warnings against use of SSRI antidepressants in under-18-year-olds. Br J Clin Pharmacol. 2009 Oct;68(4):618-29. | 9
40 | Bergman J, Miodownik C, Palatnik A, Lerner V Efficacy of bupropion XR in treatment-resistant elderly patients: a case series study. Clin Neuropharmacol. 2011 Jan-Feb;34(1):17-20. | 9
41 | Bergmans Y, Links PS. Reducing potential risk factors for suicide-related behavior with a group intervention for clients with recurrent suicide-related behavior. Ann Clin Psychiatry. 2009 Jan-Mar;21(1):17-25. | 3
42 | Bessant M, King EA, Peveler R. Characteristics of suicides in recent contact with NHS Direct. Psychiatric Bulletin. 2008 Mar;32(3):92-5. | 9
43 | Borschmann, Rohan, Henderson, et al. Crisis interventions for people with borderline personality disorder [Protocol]. Cochrane Database of Systematic Reviews. 2011 (10). | 6
44 | Bridge JA, Barbe RP, Birmaher B, Kolko DJ, Brent DA. Emergent suicidality in a clinical psychotherapy trial for adolescent depression. Am J Psychiatry. 2005 Nov;162(11):2173-5. | 9
45 | Bronisch T. Depression and Suicide: Antidepressive Therapies in the Acute and Chronic Treatment of Unipolar and Bipolar Affective Disorders - Are they Preventive According to Suicide? Krankenhauspsychiatrie. 2005 Sep;16(Suppl1):27-33. | 1
46 | Brown C, Wyman PA, Brinales JM, Gibbons RD. The role of randomized trials in testing interventions for the prevention of youth suicide. International Review of Psychiatry. 2007 Dec;19(6):617-31. | 5
47 | Burns J, Dudley M, Hazell P, Patton G Clinical management of deliberate self-harm in young people: the need for evidence-based approaches to reduce repetition. Australian and New Zealand Journal of Psychiatry. 2005;39(3):121-8. | 7
48 | Cardish RJ. Psychopharmacologic management of suicidality in personality disorders. Can J Psychiatry. 2007 Jun;52(6 Suppl 1):115S-27S. | 6
49 | Carr A. Depression in young people: description, assessment and evidence-based treatment. Dev Neurorehabil. 2008 Jan-Mar;11(1):3-15. | 6
50 | Catanese AA, John MS, Di Battista J, Clarke DM. Acute cognitive therapy in reducing suicide risk following a presentation to an emergency department. Behaviour Change. 2009 May;26(1):16-26. | 9
51 | Chiesa M, Fonagy P, Gordon J. Community-based psychodynamic treatment program for severe personality disorders: clinical description and naturalistic evaluation. J Psychiatr Pract. 2009 Jan; 15(1): 12-24. | 9
52 | Chisholm D, van Ommeren M, Ayuso-Mateos JL, Saxena S. Cost-effectiveness of clinical interventions for reducing the global burden of bipolar disorder. Br J Psychiatry. 2005 Dec;187:559-67. | 9
53 | Cipriani A, Barbui C, Geddes JR. Suicide, depression, and antidepressants. BMJ. 2005;330(7488):373-4. | 6
54 | Cipriani A, Geddes JR, Furukawa TA, Barbui C. Metareview on short-term effectiveness and safety of antidepressants for depression: an evidence-based approach to inform clinical practice. Can J Psychiatry. 2007 Sep;52(9):553-62. | 6
55 | Cipriani A, Rendell JM, Geddes JR. Haloperidol alone or in combination for acute mania. Cochrane Database Syst Rev. 2006;3:CD004362. | 3
56 | Coffey CE. Building a system of perfect depression care in behavioral health. Jt Comm J Qual Patient Saf. 2007 Apr;33(4):193-9. | 9
57 | Cohen A, Houck PR, Szanto K, Dew MA, Gilman SE, Reynolds CF, III. Social inequalities in response to antidepressant treatment in older adults. Archives of General Psychiatry. 2006 Jan;63(1):50-6. | 3
58 | Cohen D. Should the use of selective serotonin reuptake inhibitors in child and adolescent depression be banned? Psychother Psychosom. 2007;76(1):5-14. | 6
59 | Cohen VK. Keeping students alive: mandating on-campus counseling saves suicidal college students' lives and limits liability. Fordham Law Rev. 2007 May;75(6):3081-135. | 5
60 | Combalbert N, Bourdet-Loubere S. Suicide by jumping and strategies to prevent it. L'Evolution Psychiatrique. 2006 Oct-Dec;71(4):685-95. | 1
61 | Combs H, Romm S. Psychiatric inpatient suicide: A literature review. Primary Psychiatry. 2007 Dec; 14(12):67-74. | 7
62 | Comtois KA, Linehan MM. Psychosocial treatments of suicidal behaviors: a practice-friendly review. J Clin Psychol. 2006 Feb;62(2):161-70. | 6
63 | Cooper SL, Lezotte D, Jacobellis J, Diguiseppi C. Does availability of mental health resources prevent recurrent suicidal behavior? An ecological analysis. Suicide Life Threat Behav. 2006 Aug;36(4):409-17. | 9
64 | Corcoran J, Dattalo P, Crowley M, Brown E, Grindle L. A systematic review of psychosocial interventions for suicidal adolescents. Children and Youth Services Review. 2011 Nov;33(11):2112-8. | 7
65 | Coryell W. Maintenance treatment in bipolar disorder: A reassessment of lithium as the first choice. Bipolar Disorders. 2009 Jun;11(Suppl2):77-83. | 6
66 | Cottraux J, Note ID, Boutitie F, et al. Cognitive therapy versus Rogerian supportive therapy in borderline personality disorder. Two-year follow-up of a controlled pilot study. Psychother Psychosom. 2009;78(5):307-16. | 2
67 | Craig M, Howard L. Postnatal depression. Clin Evid (Online). 2009;2009. | 7
68 | Crawford MJ, Thomas O, Khan N, Kulinskaya E. Psychosocial interventions following self-harm: systematic review of their efficacy in preventing suicide. Br J Psychiatry. 2007 Jan;190:11-7. | 7
69 | Crits-Christoph P, Barber JP. Psychological treatments for personality disorders. Nathan, Peter E [Ed]. 2007:641-58. | 6
70 | Crocq MA, Naber D, Lader MH, et al. Suicide attempts in a prospective cohort of patients with schizophrenia treated with sertindole or risperidone. Eur Neuropsychopharmacol. 2010 Dec;20(12):829-38. | 2
71 | Currier GW, Fisher SG, Caine ED. Mobile crisis team intervention to enhance linkage of discharged suicidal emergency department patients to outpatient psychiatric services: a randomized controlled trial. Acad Emerg Med. 2010 Jan;17(1):36-43. | 3
72 | Cusimano MD, Sameem M. The effectiveness of middle and high school-based suicide prevention programmes for adolescents: a systematic review. Inj Prev. 2011 Feb;17(1):43-9. | 4
73 | Daigle MS, Daniel AE, Dear GE, et al. Preventing suicide in prisons, part II. International comparisons of suicide prevention services in correctional facilities. Crisis. 2007;28(3): 122-30. | 6
74 | Daigle MS, Pouliot L, Chagnon F, Greenfield B, Mishara B. Suicide attempts: prevention of repetition. Can J Psychiatry. 2011 Oct;56(10):621-9. | 7
75 | Daigle MS. Suicide prevention through means restriction: Assessing the risk of substitution: A critical review and synthesis. Accident Analysis and Prevention. 2005 Jul;37(4):625-32. | 6
76 | Daniel SS, Goldston DB. Interventions for suicidal youth: A review of the literature and developmental considerations. Suicide and Life Threatening Behavior. 2009 Jun;39(3):252-68. | 7
77 | Daviss W. A review of co-morbid depression in pediatric ADHD: Etiologies, phenomenology, and treatment. Journal of Child and Adolescent Psychopharmacology. 2008 Dec;18(6):565-71. | 6
78 | De Leo D. The world health organization: Approach to evidence-based suicide prevention. Pompili, Maurizio [Ed]. 2011:55-64. | 6
79 | Denneson LM, Basham C, Dickinson KC, et al. Suicide risk assessment and content of VA health care contacts before suicide completion by veterans in Oregon. Psychiatr Serv. 2010 Dec;61(12): 1192-7. | 5
80 | Department of Defense Task Force on the Prevention of Suicide by Members of the Armed Forces. The Challenge and the Promise: Strengthening the Force, Preventing Suicide and Saving Lives. Washington D.C.: Department of Defense; 2010. | 6
81 | Dixon L, Goldberg R, Iannone V, et al. Use of a critical time intervention to promote continuity of care after psychiatric inpatient hospitalization. Psychiatric Services. 2009;60(4):451-8. | 3
82 | Doering S, Horz S, Rentrop M, et al. Transference-focused psychotherapy v. treatment by community psychotherapists for borderline personality disorder: randomised controlled trial. Br J Psychiatry. 2010 May;196(5):389-95. | 2
83 | Doggrell SA. Fluoxetine--do the benefits outweigh the risks in adolescent major depression? Expert Opinion on Pharmacotherapy. 2005;6(1): 147-50. | 6
84 | Dombrovski AY, Mulsant BH. The evidence for electroconvulsive therapy (ECT) in the treatment of severe late-life depression. ECT: the preferred treatment for severe depression in late life. Int Psychogeriatr. 2007 Feb;19(1):10-4, 27-35; discussion 24-6. | 6
85 | Dube P, Kurt K, Bair MJ, Theobald D, Williams LS. The p4 screener: evaluation of a brief measure for assessing potential suicide risk in 2 randomized effectiveness trials of primary care and oncology patients. Prim Care Companion J Clin Psychiatry. 2010; 12(6). | 9
86 | Dubicka B, Hadley S, Roberts C. Suicidal behaviour in youths with depression treated with new-generation antidepressants: meta-analysis. Br J Psychiatry. 2006 Nov;189:393-8. | 7
87 | Dubicka B, Wilkinson P. Evidence-based treatment of adolescent major depression. Evid Based Ment Health. 2007 Nov; 10(4): 100-2. | 6
88 | Dudley M, Goldney R, Hadzi-Pavlovic D. Are adolescents dying by suicide taking SSRI antidepressants? A review of observational studies. Australasian Psychiatry. 2010 Jun;18(3):242-5. | 7
89 | Dudley M, Hadzi-Pavlovic D, Andrews D, Perich T. New-generation antidepressants, suicide and depressed adolescents: How should clinicians respond to changing evidence? Australian and New Zealand Journal of Psychiatry. 2008 Jun;42(6):456-66. | 6
90 | Ebmeier KP. No apparent difference in suicide risk between older and newer antidepressants although older drugs may increase risk of suicide attempt during the first month of treatment. Evid Based Ment Health. 2006 Aug;9(3):82. | 5
91 | Emslie GJ, Yeung PP, Kunz NR. Long-term, open-label venlafaxine extended-release treatment in children and adolescents with major depressive disorder. CNS Spectr. 2007 Mar;12(3):223-33. | 9
92 | Eskin M, Ertekin K, Demir H. Efficacy of a problem-solving therapy for depression and suicide potential in adolescents and young adults. Cognitive Therapy and Research. 2008 Apr;32(2):227-45. | 2
93 | Esposito-Smythers C, Spirito A, Uth R, LaChance H. Cognitive behavioral treatment for suicidal alcohol abusing adolescents: development and pilot testing. Am J Addict. 2006; 15 Suppl 1:126-30. | 9
94 | Everly GS, Jr., Flynn BW. Principles and practical procedures for acute psychological first aid training for personnel without mental health experience. Int J Emerg Ment Health. 2006 Spring;8(2):93-100. | 6
95 | Fergusson D, Doucette S, Glass KC, et al. Association between suicide attempts and selective serotonin reuptake inhibitors: Systematic review of randomised controlled trials. BMJ: British Medical Journal. 2005 Feb;330(7488):396. | 7
96 | Fleischhaker C, Bohme R, Sixt B, Bruck C, Schneider C, Schulz E. Dialectical Behavioral Therapy for Adolescents (DBT-A): a clinical Trial for Patients with suicidal and self-injurious Behavior and Borderline Symptoms with a one-year Follow-up. Child Adolesc Psychiatry Ment Health. 2011;5(1):3. | 9
97 | Fleischmann A, Bertolote JM, Wasserman D, et al. Effectiveness of brief intervention and contact for suicide attempters: a randomized controlled trial in five countries. Bull World Health Organ. 2008 Sep;86(9):703-9. | 2
98 | Florentine JB, Crane C. Suicide prevention by limiting access to methods: A review of theory and practice. Social Science & Medicine. 2010 May;70(10):1626-32. | 6
99 | Fountoulakis KN, Gonda X, Siamouli M, Rihmer Z. Psychotherapeutic intervention and suicide risk reduction in bipolar disorder: a review of the evidence. J Affect Disord. 2009 Feb;113(1-2):21-9. | 7
100 | Fountoulakis KN, Grunze H, Panagiotidis P, Kaprinis G Treatment of bipolar depression: An update. Journal of Affective Disorders. 2008 Jul;109(1-2):21-34. | 6
101 | Fountoulakis KN, Vieta E, Schmidt F Aripiprazole monotherapy in the treatment of bipolar disorder: A meta-analysis. J Affect Disord. 2010 Oct 30. | 7
102 | Freeman SA. Suicide risk and psychopharmacology: assessment and management of acute and chronic risk factors. J Clin Psychiatry. 2009 Jul;70(7):1052-3. | 6
103 | Fu Y-X, Shen J-L, Dang W. Effects of psychological intervention on the young people of attempted suicide. Chinese Mental Health Journal. 2007 Aug;21(8):571-4. | 1
104 | Gardner W, Klima J, Chisolm D, et al. Screening, triage, and referral of patients who report suicidal thought during a primary care visit. Pediatrics. 2010 May;125(5):945-52. | 3
105 | Garvey KA, Penn JV, Campbell AL, Esposito-Smythers C, Spirito A. Contracting for safety with patients: Clinical practice and forensic implications. Journal of the American Academy of Psychiatry and the Law. 2009 Sep;37(3):363-70. | 6
106 | Geddes JR, Barbui C, Cipriani A. Risk of suicidal behaviour in adults taking antidepressants. BMJ. 2009;339:b3066. | 5
107 | Gilbert JW, Wheeler GR, Storey BB, et al. Suicidality in chronic noncancer pain patients. Int J Neurosci. 2009;119(10):1968-79. | 9
108 | Glass JE, Ilgen MA, Winters JJ, Murray RL, Perron BE, Chermack ST. Inpatient hospitalization in addiction treatment for patients with a history of suicide attempt: A case of support for treatment performance measures. Journal of Psychoactive Drugs. 2010 Sep;42(3):315-25. | 3
109 | Goldney RD. Suicide Prevention: A Pragmatic Review of Recent Studies. Crisis: The Journal of Crisis Intervention and Suicide Prevention. 2005;26(3): 128-40. | 6
110 | Goldstein BI, Bukstein OG Comorbid substance use disorders among youth with bipolar disorder: opportunities for early identification and prevention. J Clin Psychiatry. 2010 Mar;71(3):348-58. | 6
111 | Gottman JM, Gottman JS, Atkins CL. The Comprehensive Soldier Fitness Program: Family skills component. American Psychologist. 2011 Jan;66(1):52-7. | 6
112 | Gould MS, Kalafat J, Harrismunfakh JL, Kleinman M. An evaluation of crisis hotline outcomes. Part 2: Suicidal callers. Suicide Life Threat Behav. 2007 Jun;37(3):338-52. | 9
113 | Grandjean EM, Aubry JM. Lithium: updated human knowledge using an evidence-based approach: Part I: Clinical efficacy in bipolar disorder. CNS Drugs. 2009;23(3):225-40. | 7
114 | Grawe R, Falloon I, Widen J, Skogvoll E. Two years of continued early treatment for recent-onset schizophrenia: A randomised controlled study. Acta Psychiatrica Scandinavica. 2006 Nov;114(5):328-36. | 2
115 | Greden JF, Valenstein M, Spinner J, et al. Buddy-to-Buddy, a citizen soldier peer support program to counteract stigma, PTSD, depression, and suicide. Ann N Y Acad Sci. 2010 Oct;1208:90-7. | 4
116 | Gutierrez PM, Brenner LA, Olson-Madden JH, et al. Consultation as a means of veteran suicide prevention. Professional Psychology: Research and Practice. 2009 Dec;40(6):586-92. | 6
117 | Guzzetta F, Tondo L, Centorrino F, Baldessarini RJ. Lithium treatment reduces suicide risk in recurrent major depressive disorder. J Clin Psychiatry. 2007 Mar;68(3):380-3. | 7
118 | Gyorgy P, Zoltan R. The role of sleep-improving and anxiolytic effect of mirtazapine in decreasing suicide risk in patients with depression. Psychiatria Hungarica. 2009;24(Suppl):6-11. | 1
119 | Haffner WH. Veteran suicide. Mil Med. 2010 Oct;175(10):i. | 6
120 | Hall WD, Lucke J. How have the selective serotonin reuptake inhibitor antidepressants affected suicide mortality? Australian and New Zealand Journal of Psychiatry. 2006 Nov;40(11-12):941-50. | 7
121 | Hamilton SM, Rolf KA. Suicide in adolescent American Indians: Preventative social work programs. Child & Adolescent Social Work Journal. 2010 Aug;27(4):283-90. | 6
122 | Hammad TA, Laughren T, Racoosin J. Suicidality in pediatric patients treated with antidepressant drugs. Arch Gen Psychiatry. 2006 Mar;63(3):332-9. | 3
123 | Hammad TA, Laughren TP, Racoosin JA. Suicide rates in short-term randomized controlled trials of newer antidepressants. J Clin Psychopharmacol. 2006 Apr;26(2):203-7. | 8
124 | Hammerness PG, Vivas FM, Geller DA. Selective serotonin reuptake inhibitors in pediatric psychopharmacology: a review of the evidence. J Pediatr. 2006 Feb; 148(2): 158-65. | 7
125 | Hampton T. Depression care effort brings dramatic drop in large HMO population's suicide rate. JAMA: Journal of the American Medical Association. 2010 May;303(19):1903-5. | 6
126 | Hamrin V, Scahill L. Selective serotonin reuptake inhibitors for children and adolescents with major depression: current controversies and recommendations. Issues Ment Health Nurs. 2005 May;26(4):433-50. | 6
127 | Han D, Wang EC. Remission from depression: A review of venlafaxine clinical and economic evidence. Pharmacoeconomics. 2005;23(6):567-81. | 6
128 | Harned MS, Chapman AL, Dexter-Mazza ET, Murray A, Comtois KA, Linehan MM. Treating co-occurring Axis I disorders in recurrently suicidal women with borderline personality disorder: a 2-year randomized trial of dialectical behavior therapy versus community treatment by experts. J Consult Clin Psychol. 2008 Dec;76(6): 1068-75. | 3
129 | Harrison-Woolrych M. Varenicline and suicide. Safety data from New Zealand. BMJ. 2009;339:b5654. | 6
130 | Harrod, Curtis S, Goss, et al. Interventions for primary prevention of suicide in the post-secondary educational setting [Protocol]. Cochrane Database of Systematic Reviews. 2011 (11). | 6
131 | Harter M, Bermejo I, Ollenschlager G, et al. Improving quality of care for depression: the German Action Programme for the implementation of evidence-based guidelines. Int J Qual Health Care. 2006 Apr;18(2):113-9. | 2
132 | Hassanian-Moghaddam H, Sarjami S, Kolahi AA, Carter GL. Postcards in Persia: randomised controlled trial to reduce suicidal behaviours 12 months after hospital-treated self-poisoning. Br J Psychiatry. 2011 Feb 22;198:309-16. | 2
133 | Haukka J, Arffman M, Partonen T, et al. Antidepressant use and mortality in Finland: a register-linkage study from a nationwide cohort. Eur J Clin Pharmacol. 2009 Jul;65(7):715-20. | 2
134 | Haukka J, Tiihonen J, Harkanen T, Lonnqvist J. Association between medication and risk of suicide, attempted suicide and death in nationwide cohort of suicidal patients with schizophrenia. Pharmacoepidemiol Drug Saf. 2008 Jul;17(7):686-96. | 2
135 | Hawgood J, De Leo D. Anxiety disorders and suicidal behaviour: an update. Curr Opin Psychiatry. 2008 Jan;21(1):51-64. | 7
136 | Hays JT, Ebbert JO. Adverse effects and tolerability of medications for the treatment of tobacco use and dependence. Drugs. 2010 Dec 24;70(18):2357-72. | 6
137 | Hazell P. Depression in children and adolescents. Clin Evid (Online). 2009;2009. | 3
138 | Hazell P. Depression in children and adolescents. Clin Evid (Online). 2011;2011. | 7
139 | Heisel MJ, Duberstein PR. Suicide Prevention in Older Adults. Clinical Psychology: Science and Practice. 2005 Fal;12(3):242-59. | 6
140 | Hennen J, Baldessarini RJ. Suicidal risk during treatment with clozapine: A meta-analysis. Schizophrenia Research. 2005 Mar;73(2-3):139-45. | 6
141 | Hesdorffer DC, Berg AT, Kanner AM. An update on antiepileptic drugs and suicide: are there definitive answers yet? Epilepsy Curr. 2010 Nov; 10(6):137-45. | 6
142 | Hong J, Reed C, Novick D, Haro JM, Aguado J. Clinical and economic consequences of medication non-adherence in the treatment of patients with a manic/mixed episode of bipolar disorder: Results from the European Mania in Bipolar Longitudinal Evaluation of Medication (EMBLEM) Study. Psychiatry Res. 2011 May 14. | 2
143 | Hough D, Lewis P. A suicide prevention advisory group at an academic medical center. Mil Med. 2010 May;175(5):347-51. | 6
144 | Hughes S, Cohen D. A systematic review of long-term studies of drug treated and non-drug treated depression. Journal of Affective Disorders. 2009;118(1-3):9-18. | 3
145 | Hur JW, Kim WJ, Kim YK. The Mediating Effect of Psychosocial Factors on Suicidal Probability among Adolescents. Arch Suicide Res. 2011 Oct; 15(4): 327-36. | 1
146 | Ilgen MA, Jain A, Lucas E, Moos RH. Substance use-disorder treatment and a decline in attempted suicide during and after treatment. J Stud Alcohol Drugs. 2007 Jul;68(4):503-9. | 9
147 | Ille R, Spona J, Zickl M, et al. “Add-On”-therapy with an individualized preparation consisting of free amino acids for patients with a major depression. European Archives of Psychiatry and Clinical Neuroscience. 2007 Jun;257(4):222-9. | 2
148 | Innamorati M, Pompili M, Amore M, et al. Suicide prevention in late life: Is there sound evidence for practice? In: Pompili M, Tatarelli R, eds. Evidence-based practice in suicidology: A source book. Cambridge, MA: Hogrefe Publishing; 2011:211-32. | 7
149 | Irons J. Fluvoxamine in the treatment of anxiety disorders. Neuropsychiatr Dis Treat. 2005 Dec;1(4):289-99. | 6
150 | Isaac M, Elias B, Katz LY, et al. Gatekeeper training as a preventative intervention for suicide: a systematic review. Can J Psychiatry. 2009 Apr;54(4):260-8. | 4
151 | Jacono J, Jacono B. The use of puppetry for health promotion and suicide prevention among Mi'Kmaq youth. J Holist Nurs. 2008 Mar;26(1):50-5. | 6
152 | Jakupcak M, Varra EM. Treating Iraq and Afghanistan war veterans with PTSD who are at high risk for suicide. Cognitive and Behavioral Practice. 2011 Feb;18(1):85-97. | 6
153 | Jones G, Gavrilovic JJ, McCabe R, Becktas C, Priebe S. Treating suicidal patients in an acute psychiatric day hospital: a challenge to assumptions about risk and overnight care. Journal of Mental Health. 2008;17(4):375-87. | 3
154 | Jorm AF, Kelly CM, Morgan AJ. Participant distress in psychiatric research: a systematic review. Psychol Med. 2007 Jul;37(7):917-26. | 3
155 | Juurlink DN, Mamdani MM, Kopp A, Redelmeier DA. The risk of suicide with selective serotonin reuptake inhibitors in the elderly. Am J Psychiatry. 2006 May;163(5):813-21. | 9
156 | Kaizar EE, Greenhouse JB, Seltman H, Kelleher K. Do antidepressants cause suicidality in children? A Bayesian meta-analysis. Clin Trials. 2006;3(2):73-90; discussion 1-8. | 8
157 | Kanner AM. Depression and epilepsy: A review of multiple facets of their close relation. Neurologic Clinics. 2009 Nov;27(4):865-80. | 6
158 | Karayal ON, Anway SD, Batzar E, Vanderburg DG Assessments of suicidality in double-blind, placebo-controlled trials of ziprasidone. J Clin Psychiatry. 2011 Mar;72(3):367-75. | 6
159 | Kaslow NJ, Leiner AS, Reviere S, et al. Suicidal, abused African American women's response to a culturally informed intervention. Journal of Consulting and Clinical Psychology. 2010 Aug;78(4):449-58. | 3
160 | Kasper S, Montgomery SA, Moller HJ, et al. Longitudinal analysis of the suicidal behaviour risk in short-term placebo-controlled studies of mirtazapine in major depressive disorder. World J Biol Psychiatry. 2010 Feb;11(1):36-44. | 3
161 | Kennard BD, Silva SG, Mayes TL, et al. Assessment of safety and long-term outcomes of initial treatment with placebo in TADS. The American Journal of Psychiatry. 2009 Mar;166(3):337-44. | 3
162 | Kennedy CH, Cook JH, Poole DR, Brunson CL, Jones DE. Review of the first year of an overseas military gambling treatment program. Mil Med. 2005 Aug;170(8):683-7. | 9
163 | Kennedy SH, Giacobbe P, Rizvi SJ, et al. Deep brain stimulation for treatment-resistant depression: follow-up after 3 to 6 years. Am J Psychiatry. 2011 May;168(5):502-10. | 9
164 | Keshtkar M, Ghanizadeh A, Firoozabadi A. Repetitive Transcranial Magnetic Stimulation Versus Electroconvulsive Therapy for the Treatment of Major Depressive Disorder, A Randomized Controlled Clinical Trial. J ECT 2011 Nov 9. | 2
165 | Kessing LV, Sondergard L, Kvist K, Andersen PK. Suicide risk in patients treated with lithium. Arch Gen Psychiatry. 2005 Aug;62(8):860-6. | 2
166 | Kim HM, Eisenberg D, Ganoczy D, et al. Examining the relationship between clinical monitoring and suicide risk among patients with depression: matched case-control study and instrumental variable approaches. Health Serv Res. 2010 Oct;45(5 Pt 1):1205-26. | 9
167 | Klein DF. The flawed basis for FDA post-marketing safety decisions: the example of antidepressants and children. Neuropsychopharmacology. 2006 Apr;31(4):689-99. | 6
168 | Knox KL, Pflanz S, Talcott GW, et al. The US Air Force suicide prevention program: implications for public health policy. Am J Public Health. 2010 Dec;100(12):2457-63. | 9
169 | Koehn CV, Cutcliffe JR. Hope and interpersonal psychiatric/mental health nursing: a systematic review of the literature--part one. J Psychiatr Ment Health Nurs. 2007 Apr; 14(2):134-40. | 7
170 | Kolla NJ, Eisenberg H, Links PS. Epidemiology, risk factors, and psychopharmacological management of suicidal behavior in borderline personality disorder. Archives of Suicide Research. 2008 Jan; 12(1): 1-19. | 7
171 | Konrad N, Daigle MS, Daniel AE, et al. Preventing suicide in prisons, part I. Recommendations from the International Association for Suicide Prevention Task Force on Suicide in Prisons. Crisis. 2007;28(3): 113-21. | 6
172 | Kostenuik M, Ratnapalan M. Approach to adolescent suicide prevention. Can Fam Physician. 2010 Aug;56(8):755-60. | 6
173 | Kratochvil CJ, Vitiello B, Walkup J, et al. Selective serotonin reuptake inhibitors in pediatric depression: is the balance between benefits and risks favorable? J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(1-2): 11-24. | 8
174 | Kryzhanovskaya LA, Robertson-Plouch CK, Xu W, Carlson JL, Merida KM, Dittmann RW. The safety of olanzapine in adolescents with schizophrenia or bipolar I disorder: a pooled analysis of 4 clinical trials. J Clin Psychiatry. 2009 Feb;70(2):247-58. | 6
175 | Kutcher S, Gardner DM. Use of selective serotonin reuptake inhibitors and youth suicide: Making sense from a confusing story. Current Opinion in Psychiatry. 2008 Jan;21(1):65-9. | 6
176 | Lapierre S, Dube M, Bouffard L, Alain M. Addressing suicidal ideations through the realization of meaningful personal goals. Crisis. 2007;28(1):16-25. | 3
177 | Lapierre S, Erlangsen A, Waern M, et al. A systematic review of elderly suicide prevention programs. Crisis. 2011 Jan 1;32(2):88-98. | 7
178 | Lauterbach E, Felber W, Muller-Oerlinghausen B, et al. Adjunctive lithium treatment in the prevention of suicidal behaviour in depressive disorders: a randomised, placebo-controlled, 1-year trial. Acta Psychiatr Scand. 2008 Dec;118(6):469-79. | 2
179 | Leenaars AA. Evidence-based psychotherapy with suicidal people: A systematic review. Pompili, Maurizio [Ed]. 2011:89-123. | 7
180 | Leenaars AA. Psychotherapy with Suicidal People: The Commonalities. Archives of Suicide Research. 2006 Dec;10(4):305-22. | 6
181 | Leon AC, Solomon DA, Li C, et al. Antidepressants and risks of suicide and suicide attempts: a 27-year observational study. Journal of Clinical Psychiatry. 2011;72(5):580-6. | 9
182 | Lester D. Resources and Tactics for Preventing Suicide. Clinical Neuropsychiatry: Journal of Treatment Evaluation. 2005 Feb;2(1):32-6. | 5
183 | Lester D. The use of the Internet for counseling the suicidal individual: possibilities and drawbacks. Omega (Westport). 2008;58(3):233-50. | 6
184 | Levy KN, Meehan KB, Yeomans FE. Transference-focused psychotherapy reduces treatment drop-out and suicide attempters compared with community psychotherapist treatment in borderline personality disorder. Evid Based Ment Health. 2010 Nov;13(4):119. | 2
185 | Lewis LM. No-harm contracts: A review of what we know. Suicide and Life Threatening Behavior. 2007 Feb;37(1):50-7. | 6
186 | Licinio J, Wong M-L. Depression, antidepressants and suicidality: a critical appraisal. Nat Rev Drug Discov. 2005;4(2):165-71. | 6
187 | Links PS, Hoffman B. Preventing suicidal behaviour in a general hospital psychiatric service: priorities for programming. Can J Psychiatry. 2005 Jul;50(8):490-6. | 7
188 | Lizardi D, Stanley B. Treatment engagement: A neglected aspect in the psychiatric care of suicidal patients. Psychiatric Services. 2010 Dec;61(12):1183-91. | 7
189 | Long CG, Fulton B, Dolley O, Hollin CR. Dealing with Feelings: the effectiveness of cognitive behavioural group treatment for women in secure settings. Behav Cogn Psychother. 2011 Mar;39(2):243-7. | 9
190 | Lorillard S, Schmitt L, Andreoli A. How to treat deliberate self-harm: From clinical research to effective treatment choice? Part 1: An update treatment efficacy among unselected patients referred to emergency room with deliberate self-harm. Annales Medico-Psychologiques. 2011 May;169(4):221-8. | 1
191 | Lorillard S, Schmitt L, Andreoli A. How to treat suicide attempt? Part 2: A review of treatments and their efficiency among borderline personality disorder patients. Annales Medico-Psychologiques. 2011 May;169(4):229-36. | 1
192 | Lu YJ, Chang HJ, Tung YY, Hsu MC, Lin MF. Alleviating psychological distress of suicide survivors: evaluation of a volunteer care programme. J Psychiatr Ment Health Nurs. 2011 Jun;18(5):449-56. | 3
193 | Ludwig J, Marcotte DE, Norberg K. Anti-depressants and suicide. J Health Econ 2009 May;28(3):659-76. | 2
194 | Lynch MA, Howard PB, El-Mallakh P, Matthews JM. Assessment and management of hospitalized suicidal patients. J Psychosoc Nurs Ment Health Serv. 2008 Jul;46(7):45-52. | 6
195 | Malmberg, Lena, Fenton, Mark, Rathbone, John. Individual psychodynamic psychotherapy and psychoanalysis for schizophrenia and severe mental illness [Systematic Review]. Cochrane Database of Systematic Reviews. 2010 (3). | 3
196 | Malone D, Newron-Howes G, Simmonds S, Marriot S, Tyrer P. Community mental health teams (CMHTs) for people with severe mental illnesses and disordered personality. Cochrane Database Syst Rev. 2007 (3):CD000270. | 3
197 | Mamo DC. Managing suicidality in schizophrenia. Can J Psychiatry. 2007 Jun;52(6 Suppl 1):59S-70S. | 7
198 | Mann J, Currier D. Evidence-based suicide prevention strategies: An overview. Pompili, Maurizio [Ed]. 2011:67-87. | 6
199 | Manna M. Effectiveness of formal observation in inpatient psychiatry in preventing adverse outcomes: The state of the science. Journal of Psychiatric and Mental Health Nursing. 2010 Apr;17(3):268-73. | 7
200 | Manthorpe J, Iliffe S. Social work with older people--Reducing suicide risk: A critical review of practice and prevention. British Journal of Social Work. 2011 Jan;41(1): 131-47. | 6
201 | Marangell LB, Dennehy EB, Wisniewski SR, et al. Case-control analyses of the impact of pharmacotherapy on prospectively observed suicide attempts and completed suicides in bipolar disorder: findings from STEP-BD. J Clin Psychiatry. 2008 Jun;69(6):916-22. | 9
202 | March JS, Klee BJ, Kremer CM. Treatment benefit and the risk of suicidality in multicenter, randomized, controlled trials of sertraline in children and adolescents. J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(1-2):91-102. | 8
203 | Matakas F, Rohrbach E. Suicide prevention in the psychiatric hospital. Suicide Life Threat Behav. 2007 Oct;37(5):507-17. | 2
204 | McAuliffe N, Perry L. Making it safer: a health centre's strategy for suicide prevention. Psychiatr Q. 2007 Dec;78(4):295-307. | 3
205 | McElroy SL, Kotwal R, Kaneria R, Keck PE, Jr. Antidepressants and suicidal behavior in bipolar disorder. Bipolar Disorders. 2006 Oct;8(5 pt 2):596-617. | 7
206 | McMain S. Effectiveness of psychosocial treatments on suicidality in personality disorders. Can J Psychiatry. 2007 Jun;52(6 Suppl 1):103S-14S. | 7
207 | McQuillan A, Nicastro R, Guenot F, Girard M, Lissner C, Ferrero F Intensive Dialectical Behavior Therapy for Outpatients With Borderline Personality Disorder Who Are in Crisis. Psychiatric Services. 2005 Feb;56(2):193-7. | 2
208 | Melle I, Johannessen JO, Friis S, et al. Course and predictors of suicidality over the first two years of treatment in first-episode schizophrenia spectrum psychosis. Arch Suicide Res. 2010 Apr;14(2):158-70. | 2
209 | Melvin GA, Tonge BJ, King NJ, Heyne D, Gordon MS, Klimkeit E. A comparison of cognitive-behavioral therapy, sertraline, and their combination for adolescent depression. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45(10): 1151-61. | 3
210 | Merrick J, Merrick E, Lunsky Y, Kandel I. Review of suicidality in persons with intellectual disability. Israel Journal of Psychiatry and Related Sciences. 2006;43(4):258-64. | 6
211 | Mishara BL, Chagnon F, Daigle M, et al. Which helper behaviors and intervention styles are related to better short-term outcomes in telephone crisis intervention? Results from a Silent Monitoring Study of Calls to the U.S. 1-800-SUICIDE Network. Suicide Life Threat Behav. 2007 Jun;37(3):308-21. | 3
212 | Mishara BL, Houle J, Lavoie B. Comparison of the effects of four suicide prevention programs for family and friends of high-risk suicidal men who do not seek help themselves. Suicide Life Threat Behav. 2005 Jun;35(3):329-42. | 9
213 | Mitchell SA. Examining the effectiveness of a school-based mental health center's services. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2008;68(8-A):3282. | 3
214 | Moller HJ. Evidence for beneficial effects of antidepressants on suicidality in depressive patients: a systematic review. Eur Arch Psychiatry Clin Neurosci. 2006 Sep;256(6):329-43. | 6
215 | Morriss R, Gask L, Webb R, Dixon C, Appleby L. The effects on suicide rates of an educational intervention for front-line health professionals with suicidal patients (the STORM Project). Psychol Med. 2005 Jul;35(7):957-60. | 4
216 | Mortimer AM, Singh P, Shepherd CJ, Puthiryackal J. Clozapine for treatment-resistant schizophrenia: National Institute of Clinical Excellence (NICE) guidance in the real world. Clin Schizophr Relat Psychoses. 2010 Apr;4(1):49-55. | 3
217 | Mosholder AD, Willy M. Suicidal adverse events in pediatric randomized, controlled clinical trials of antidepressant drugs are associated with active drug treatment: a meta-analysis. J Child Adolesc Psychopharmacol. 2006 Feb-Apr;16(1-2):25-32. | 8
218 | Mowla A, Kardeh E. Topiramate augmentation in patients with resistant major depressive disorder: a double-blind placebo-controlled clinical trial. Prog Neuropsychopharmacol Biol Psychiatry. 2011 Jun 1;35(4):970-3. | 2
219 | Mulder RT, Joyce PR, Frampton CM, Luty SE. Antidepressant treatment is associated with a reduction in suicidal ideation and suicide attempts. Acta Psychiatr Scand. 2008 Aug;118(2):116-22. | 9
220 | Muller-Oerlinghausen B, Felber W, Berghofer A, Lauterbach E, Ahrens B. The Impact of Lithium Long-Term Medication on Suicidal Behavior and Mortality of Bipolar Patients. Archives of Suicide Research. 2005 Sep;9(3):307-19. | 6
221 | Muller-Oerlinghausen B, Lewitzka U. Lithium reduces pathological aggression and suicidality: A mini-review. Neuropsychobiology. 2010 Jun;62(1):43-9. | 6
222 | Musselman DL, Somerset WI, Guo Y, et al. A double-blind, multicenter, parallel-group study of paroxetine, desipramine, or placebo in breast cancer patients (stages I, II, III, and IV) with major depression. Journal of Clinical Psychiatry. 2006;67(2):288-96. | 3
223 | Najavits LM, Schmitz M, Gotthardt S, Weiss RD. Seeking safety plus exposure therapy: An outcome study on dual diagnosis men. Journal of Psychoactive Drugs. 2005 Dec;37(4):425-35. | 9
224 | Nakagawa M, Yamada T, Yamada S, Natori M, Hirayasu Y, Kawanishi C. Follow-up study of suicide attempters who were given crisis intervention during hospital stay: Pilot study. Psychiatry and Clinical Neurosciences. 2009 Feb;63(1): 122-3. | 6
225 | Navarro-Mancilla AA, Rueda-Jaimes GE. Internet Addiction: A Critical Review of the Literature. Revista Colombiana de Psiquiatria. 2007 Dec;36(4):691-700. | 1
226 | Naylor PB, Cowie HA, Walters SJ, Talamelli L, Dawkins J. Impact of a mental health teaching programme on adolescents. Br J Psychiatry. 2009 Apr;194(4):365-70. | 3
227 | Neacsiu AD, Rizvi SL, Linehan MM. Dialectical behavior therapy skills use as a mediator and outcome of treatment for borderline personality disorder. Behaviour Research and Therapy. 2010 Sep;48(9):832-9. | 9
228 | Nelson JC, Delucchi K, Schneider L. Suicidal thinking and behavior during treatment with sertraline in late-life depression. Am J Geriatr Psychiatry. 2007 Jul;15(7):573-80. | 3
229 | Olmsted CL, Kockler DR. Topiramate for alcohol dependence. Ann Pharmacother. 2008 Oct;42(10):1475-80. | 7
230 | Omar HA. A model program for youth suicide prevention. Int J Adolesc Med Health. 2005 Jul-Sep;17(3):275-8. | 4
231 | Oordt MS, Jobes DA, Rudd M, et al. Development of a Clinical Guide to Enhance Care for Suicidal Patients. Professional Psychology: Research and Practice. 2005 Apr;36(2):208-18. | 6
232 | Oquendo MA, Chaudhury SR, Mann J. Pharmacotherapy of Suicidal Behavior in Bipolar Disorder. Archives of Suicide Research. 2005 Sep;9(3):237-50. | 6
233 | Owens C, Lambert H, Donovan J, Lloyd KR. A qualitative study of help seeking and primary care consultation prior to suicide. Br J Gen Pract. 2005 Jul;55(516):503-9. | 3
234 | Owens C, Owen G, Lambert H, et al. Public involvement in suicide prevention: understanding and strengthening lay responses to distress. BMC Public Health. 2009;9:308. | 3
235 | Oxman TE, Dietrich AJ, Schulberg HC. Evidence-based models of integrated management of depression in primary care. Psychiatr Clin North Am. 2005 Dec;28(4):1061-77. | 6
236 | Page SA, King MC. No-suicide agreements: current practices and opinions in a Canadian urban health region. Can J Psychiatry. 2008 Mar;53(3): 169-76. | 3
237 | Palmer S. Suicide statistics for the UK and the National Suicide Prevention Strategy. Palmer, Stephen [Ed]. 2008:27-47. | 6
238 | Parellada M, Saiz P, Moreno D, et al. Is attempted suicide different in adolescent and adults? Psychiatry Res. 2008 Jan 15; 157(1-3): 131-7. | 2
239 | Pasieczny N, Connor J. The effectiveness of dialectical behaviour therapy in routine public mental health settings: An Australian controlled trial. Behaviour Research and Therapy. 2011 Jan;49(1):4-10. | 9
240 | Pena JB, Caine ED. Screening as an Approach for Adolescent Suicide Prevention. Suicide and Life Threatening Behavior. 2006 Dec;36(6):614-37. | 7
241 | Perahia DGS, Wang F, Mallinckrodt CH, Walker DJ, Detke MJ. Duloxetine in the treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. European Psychiatry: the Journal of the Association of European Psychiatrists. 2006;21(6):367-78. | 2
242 | Phelan JC, Sinkewicz M, Castille DM, Huz S, Muenzenmaier K, Link BG Effectiveness and outcomes of assisted outpatient treatment in New York State. Psychiatr Serv. 2010 Feb;61(2):137-43. | 3
243 | Phillips KA. Suicidality in body dysmorphic disorder. Primary Psychiatry. 2007 Dec;14(12):58-66. | 6
244 | Pirruccello LM. Preventing adolescent suicide: a community takes action. J Psychosoc Nurs Ment Health Serv. 2010 May;48(5):34-41. | 6
245 | Pompili M, Innamorati M, Girardi P, Tatarelli R, Lester D. Evidence-based interventions for preventing suicide in youths. In: Pompili M, Tatarelli R, eds. Evidence-based practice in suicidology: A source book. Cambridge, MA: Hogrefe Publishing; 2011:171-209. | 7
246 | Pompili M, Innamorati M, Tatarelli R. Suicide and anorexia nervosa. Minerva Psichiatrica. 2007 Dec;48(4):387-96. | 1
247 | Poon LH, Kang GA, Lee AJ. Role of tetrabenazine for Huntington's disease-associated chorea. Ann Pharmacother. 2010 Jun;44(6):1080-9. | 5
248 | Portzky G, van Heeringen K. Suicide prevention in adolescents: a controlled study of the effectiveness of a school-based psycho-educational program. J Child Psychol Psychiatry. 2006 Sep;47(9):910-8. | 2
249 | Posner K, Oquendo MA, Gould M, Stanley B, Davies M. Columbia Classification Algorithm of Suicide Assessment (C-CASA): classification of suicidal events in the FDA's pediatric suicidal risk analysis of antidepressants. Am J Psychiatry. 2007 Jul;164(7):1035-43. | 6
250 | Posternak MA, Zimmerman M. Therapeutic effect of follow-up assessments on antidepressant and placebo response rates in antidepressant efficacy trials: meta-analysis. British Journal of Psychiatry. 2007;190:287-92. | 7
251 | Power L, Morgan S, Byrne S, et al. A pilot study evaluating a support programme for parents of young people with suicidal behaviour. Child and Adolescent Psychiatry and Mental Health. 2009 Jul;3:20. | 3
252 | Prabhu SL, Molinari V, Bowers T, Lomax J. Role of the family in suicide prevention: An attachment and family systems perspective. Bulletin of the Menninger Clinic. 2010 Fal;74(4):301-27. | 7
253 | Prendergast N, McCausland J. Dialectic behaviour therapy: A 12-month collaborative program in a local community setting. Behaviour Change. 2007 Mar;24(1):25-35. | 9
254 | Raja M, Azzoni A, Koukopoulos AE. Psychopharmacological treatment before suicide attempt among patients admitted to a psychiatric intensive care unit. J Affect Disord. 2009 Feb;113(1-2):37-44. | 2
255 | Raja M, Azzoni A. Are antidepressants warranted in the treatment of patients who present suicidal behavior? Hum Psychopharmacol. 2008 Dec;23(8):661-8. | 2
256 | Read J, Bentall R. The effectiveness of electroconvulsive therapy: a literature review. Epidemiol Psichiatr Soc. 2010 Oct-Dec;19(4):333-47. | 7
257 | Reardon CL, Factor RM. Sport psychiatry: a systematic review of diagnosis and medical treatment of mental illness in athletes. Sports Med. 2010 Nov 1;40(11):961-80. | 6
258 | Redden L, Pritchett Y, Robieson W, et al. suicidality and divalproex sodium: Analysis of controlled studies in multiple indications. Annals of General Psychiatry. 2011 Jan; 10:1. | 8
259 | Reeves H, Batra S, May RS, Zhang R, Dahl DC, Li X. Efficacy of risperidone augmentation to antidepressants in the management of suicidality in major depressive disorder: a randomized, double-blind, placebo-controlled pilot study. J Clin Psychiatry. 2008 Aug;69(8):1228-336. | 3
260 | Reeves RR, Ladner ME. Antidepressant-induced suicidality: An update. CNS Neuroscience & Therapeutics. 2010 Aug;16(4):227-34. | 6
261 | Reyes VA, Hicklin TA. Anger in the combat zone. Mil Med. 2005 Jun;170(6):483-7. | 6
262 | Rhee WK, Merbaum M, Strube MJ, Self SM. Efficacy of brief telephone psychotherapy with callers to a suicide hotline. Suicide Life Threat Behav. 2005 Jun;35(3):317-28. | 3
263 | Ricciardi A, McAllister V, Dazzan P. Is early intervention in psychosis effective? Epidemiologia e Psichiatria Sociale. 2008 Jul-Sep;17(3):227-35. | 6
264 | Richa N, Richa S, Salloum S, Baddoura C, Millet B, Mirabel-Sarron C. Familial risk factors influencing the course and the evolution of bipolar disorder: Literature review. Journal de Therapie Comportementale et Cognitive. 2009 Dec;19(4):141-5. | 1
265 | Rihmer Z, Akiskal H. Do antidepressants t(h)reat(en) depressives? Toward a clinically judicious formulation of the antidepressant-suicidality FDA advisory in light of declining national suicide statistics from many countries. Journal of Affective Disorders. 2006 Aug;94(1-3):3-13. | 6
266 | Rihmer Z, Gonda X. The Effect of Pharmacotherapy on Suicide Rates in Bipolar Patients. CNS Neurosci Ther 2011 Aug 1. | 6
267 | Ritschel LA. Does mindfulness matter? investigating the effectiveness of an outpatient dialectical behavior therapy program. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2006;67(6-B):3464. | 3
268 | Robertson HT, Allison DB. Drugs associated with more suicidal ideations are also associated with more suicide attempts. PLoS One. 2009;4(10):e7312. | 9
269 | Robinson DS, Gilmor ML, Yang Y, et al. Treatment effects of selegiline transdermal system on symptoms of major depressive disorder: a meta-analysis of short-term, placebo-controlled, efficacy trials. Psychopharmacol Bull. 2007;40(3):15-28. | 6
270 | Robinson J, Hetrick S, Gook S, et al. Study protocol: the development of a randomised controlled trial testing a postcard intervention designed to reduce suicide risk among young help-seekers. BMC Psychiatry. 2009;9(59). | 6
271 | Robinson J, Hetrick SE, Martin C. Preventing suicide in young people: systematic review. Aust N Z J Psychiatry. 2011 Jan;45(1):3-26. | 7
272 | Rodgers PL, Sudak HS, Silverman MM, Litts DA. Evidence-based practices project for suicide prevention. Suicide Life Threat Behav. 2007 Apr;37(2): 154-64. | 5
273 | Rubino A, Roskell N, Tennis P, Mines D, Weich S, Andrews E. Risk of suicide during treatment with venlafaxine, citalopram, fluoxetine, and dothiepin: retrospective cohort study. BMJ. 2007 Feb 3;334(7587):242. | 9
274 | Rucci P, Frank E, Scocco P, et al. Treatment-emergent suicidal ideation during 4 months of acute management of unipolar major depression with SSRI pharmacotherapy or interpersonal psychotherapy in a randomized clinical trial. Depress Anxiety. 2011 Apr;28(4):303-9. | 2
275 | Russell G, Owens D. Psychosocial assessment following self-harm: Repetition of nonfatal self-harm after assessment by psychiatrists or mental health nurses. Crisis: The Journal of Crisis Intervention and Suicide Prevention. 2010;31(4):211-6. | 9
276 | Safer DJ, Zito JM. Do antidepressants reduce suicide rates? Public Health. 2007 Apr;121(4):274-7. | 6
277 | Sakinofsky I. Treating suicidality in depressive illness. Part 1: current controversies. Can J Psychiatry. 2007 Jun;52(6 Suppl 1):71S-84S. | 7
278 | Sakinofsky I. Treating suicidality in depressive illness. Part 2: does treatment cure or cause suicidality? Can J Psychiatry. 2007 Jun;52(6 Suppl 1):85S-101S. | 7
279 | Salvatore T. Peer specialists can prevent suicides. Behav Healthc. 2010 Oct;30(9):31-2. | 6
280 | Sambrook S, Abba N, Chadwick P. Evaluation of DBT emotional coping skills groups for people with parasuicidal behaviours. Behavioural and Cognitive Psychotherapy. 2007 Apr;35(2):241-4. | 3
281 | Sammet l, Brockmann J, Schauenburg H. Therapeutic intervention in suicidal states--An empirical based case study on the basis of the Control-Mastery Theory. Forum der Psychoanalyse: Zeitschrift fur klinische Theorie & Praxis. 2007 Mar;23(1):18-32. | 1
282 | Schneeweiss S, Patrick AR, Solomon DH, et al. Comparative safety of antidepressant agents for children and adolescents regarding suicidal acts. Pediatrics. 2010 May;125(5):876-88. | 9
283 | Schneeweiss S, Patrick AR, Solomon DH, et al. Variation in the risk of suicide attempts and completed suicides by antidepressant agent in adults: a propensity score-adjusted analysis of 9 years' data. Arch Gen Psychiatry. 2010 May;67(5):497-506. | 9
284 | Scholz BA, Hammonds CL, Boomershine CS. Duloxetine for the management of fibromyalgia syndrome. J Pain Res. 2009;2:99-108. | 6
285 | Schumock GT, Lee TA, Joo MJ, Valuck RJ, Stayner LT, Gibbons RD. Association between Leukotriene-Modifying Agents and Suicide: What is the Evidence? Drug Saf. 2011 Jul 1;34(7):533-44. | 7
286 | Seemuller F, Lewitzka U, Muller HJ. In people taking antidepressants, suicidal behaviour is less common when they are taking them than in unexposed periods. Evid Based Ment Health. 2011 Nov;14(4):98. | 6
287 | Shern D. Examining costs and benefits in the health care debate. Psychiatric Services. 2009 Apr;60(4):419. | 6
288 | Simon GE, Savarino J, Operskalski B, Wang PS. Suicide risk during antidepressant treatment. Am J Psychiatry. 2006 Jan;163(1):41-7. | 9
289 | Simpson G, Franke B, Gillett L. Suicide prevention training outside the mental health service system: evaluation of a state-wide program in Australia for rehabilitation and disability staff in the field of traumatic brain injury. Crisis. 2007;28(1):35-43. | 3
290 | Singh T, Williams K. Atypical depression. Psychiatry. 2006 Apr;3(4):33-9. | 3
291 | Sinyor M, Levitt AJ. Effect of a barrier at Bloor Street Viaduct on suicide rates in Toronto: natural experiment. BMJ. 2010;341:c2884. | 4
292 | Siyez DM. Prevention of Suicides during Adolescence: A Review. Cocuk ve Genclik Ruh Sagligi Dergisi. 2005;12(2):92-101. | 1
293 | Skegg K, Herbison P. Effect of restricting access to a suicide jumping site. Aust N Z J Psychiatry. 2009 Jun;43(6):498-502. | 4
294 | Slee N, Garnefski N, van der Leeden R, Arensman E, Spinhoven P. Cognitive-behavioural intervention for self-harm: Randomised controlled trial. British Journal of Psychiatry. 2008 Mar;192(3):202-11. | 2
295 | Smith EG, Craig TJ, Ganoczy D, Walters HM, Valenstein M. Treatment of Veterans with depression who died by suicide: timing and quality of care at last Veterans Health Administration visit. J Clin Psychiatry. 2011 Sep 7;72(5):622-9. | 5
296 | Soomro GM. Deliberate self-harm (and attempted suicide). Clin Evid (Online). 2008;12:1012. | 7
297 | Spirito A, Simon V, Cancilliere MK, et al. Outpatient psychotherapy practice with adolescents following psychiatric hospitalization for suicide ideation or a suicide attempt. Clin Child Psychol Psychiatry. 2011 Jan;16(1):53-64. | 3
298 | Stanley B, Brown G, Brent DA, et al. Cognitive-behavioral therapy for suicide prevention (CBT-SP): treatment model, feasibility, and acceptability. Journal of the American Academy of Child and Adolescent Psychiatry. 2009 Oct;48(10): 1005-13. | 3
299 | Stanley N, Mallon S, Bell J, Manthorpe J. Suicidal students' use of and attitudes to primary care support services. Primary Health Care Research and Development. 2010 Oct;11(4):315-25. | 3
300 | Stapleton J. Do the 10 UK suicides among those taking the smoking cessation drug varenicline suggest a causal link? Addiction. 2009 May;104(5):864-5. | 6
301 | Steele MM, Doey T. Suicidal behaviour in children and adolescents. Part 2: treatment and prevention. Can J Psychiatry. 2007 Jun;52(6 Suppl 1):35S-45S. | 7
302 | Stewart C, Rapp-Paglicci L, Rowe W. Evaluating the efficacy of the prodigy prevention program across urban and rural locales. Child & Adolescent Social Work Journal. 2009 Feb;26(1):65-75. | 3
303 | Stiffman AR, Brown E, Striley CW, Ostmann E, Chowa G. Cultural and Ethical Issues Concerning Research on American Indian Youth. Ethics & Behavior. 2005;15(1):1-14. | 3
304 | Stone M, Laughren T, Jones ML, et al. Risk of suicidality in clinical trials of antidepressants in adults: analysis of proprietary data submitted to US Food and Drug Administration. BMJ. 2009;339:b2880. | 8
305 | Takada M, Shima S. Characteristics and effects of suicide prevention programs: comparison between workplace and other settings. Ind Health. 2010;48(4):416-26. | 7
306 | Tarrier N, Taylor K, Gooding P. Cognitive-behavioral interventions to reduce suicide behavior: a systematic review and meta-analysis. Behav Modif. 2008 Jan;32(1):77-108. | 3
307 | Thomas SH, Drici MD, Hall GC, et al. Safety of sertindole versus risperidone in schizophrenia: principal results of the sertindole cohort prospective study (SCoP). Acta Psychiatrica Scandinavica. 2010 Nov;122(5):345-55. | 2
308 | Thuile J, Even C, Guelfi J. Mixed states in bipolar disorders: A review of current therapeutic strategies. L'Encephale: Revue de psychiatrie clinique biologique et therapeutique. 2005 Nov;31(5):617-23. | 1
309 | Tint A, Haddad PM, Anderson IM The effect of rate of antidepressant tapering on the incidence of discontinuation symptoms: a randomised study. J Psychopharmacol. 2008 May;22(3):330-2. | 3
310 | Tondo L, Baldessarini RJ. Long-term lithium treatment in the prevention of suicidal behavior in bipolar disorder patients. Epidemiol Psichiatr Soc. 2009 Jul-Sep;18(3):179-83. | 6
311 | Tundo A, Cavalieri P, Navari S, Marchetti F. Treating bipolar depression - antidepressants and alternatives: A critical review of the literature. Acta Neuropsychiatrica. 2011 Jun;23(3):94-105. | 7
312 | Vaiva G, Ducrocq F, Meyer P, et al. Effect of telephone contact on further suicide attempts in patients discharged from an emergency department: randomised controlled study. BMJ. 2006 May 27;332(7552):1241-5. | 2
313 | Vaiva G, Walter M, Al Arab AS, et al. ALGOS: the development of a randomized controlled trial testing a case management algorithm designed to reduce suicide risk among suicide attempters. BMC Psychiatry. 2011; 11:1. | 6
314 | van de Loo-Neus GH, Rommelse N, Buitelaar JK. To stop or not to stop? How long should medication treatment of attention-deficit hyperactivity disorder be extended? Eur Neuropsychopharmacol. 2011 Aug;21(8):584-99. | 7
315 | van den Bosch LM, Koeter MW, Stijnen T, Verheul R, van den Brink W. Sustained efficacy of dialectical behaviour therapy for borderline personality disorder. Behav Res Ther. 2005 Sep;43(9):1231-41. | 2
316 | van den Bosch LM, Verheul R. Patients with addiction and personality disorder: Treatment outcomes and clinical implications. Current Opinion in Psychiatry. 2007 Jan;20(1):67-71. | 6
317 | van der Feltz-Cornelis CM, Sarchiapone M, Postuvan V, et al. Best Practice Elements of Multilevel Suicide Prevention Strategies. Crisis. 2011 Sep 26:1-15. | 7
318 | van Wel EB, Bos EH, Appelo MT, Berendsen EM, Willgeroth FC, Verbraak MJ. [The efficacy of the systems training for emotional predictability and problem solving (STEPPS) in the treatment of borderline personality disorder. A randomized controlled trial]. Tijdschr Psychiatr. 2009;51(5):291-301. | 1
319 | von Knorring AL, Olsson GI, Thomsen PH, Lemming OM, Hulten A. A randomized, double-blind, placebo-controlled study of citalopram in adolescents with major depressive disorder. J Clin Psychopharmacol. 2006 Jun;26(3):311-5. | 2
320 | Wallin MT, Wilken JA, Turner AP, Williams RM, Kane R. Depression and multiple sclerosis: Review of a lethal combination. J Rehabil Res Dev. 2006 Jan-Feb;43(1):45-62. | 6
321 | Warner CH, Appenzeller GN, Parker JR, Warner C, Diebold CJ, Grieger T. Suicide prevention in a deployed military unit. Psychiatry. 2011 Summer;74(2): 127-41. | 5
322 | Warner CH, Breitbach JE, Appenzeller GN, Yates V, Grieger T, Webster WG Division mental health in the new brigade combat team structure: part II. Redeployment and postdeployment. Mil Med. 2007 Sep;172(9):912-7. | 9
323 | Weinberg I, Ronningstam E, Goldblatt MJ, Schechter M, Wheelis J, Maltsberger JT. Strategies in treatment of suicidality: identification of common and treatment-specific interventions in empirically supported treatment manuals. J Clin Psychiatry. 2010 Jun;71(6):699-706. | 7
324 | Weisler RH, Khan A, Trivedi MH, et al. Analysis of suicidality in pooled data from 2 double-blind, placebo-controlled aripiprazole adjunctive therapy trials in major depressive disorder. J Clin Psychiatry. 2011 Apr;72(4):548-55. | 6
325 | Wen B, Zhang Q-M, Li W-B. Effects of group counseling on depression and anxiety of patients with schizophrenia in rehabilitation. Chinese Mental Health Journal. 2006 Nov;20(11):762-4. | 1
326 | Wilcox HC, Kellam SG, Brown CH, et al. The impact of two universal randomized first- and second-grade classroom interventions on young adult suicide ideation and attempts. Drug Alcohol Depend. 2008 Jun 1;95 Suppl 1:S60-73. | 4
327 | Williams JM, Alatiq Y, Crane C, et al. Mindfulness-based Cognitive Therapy (MBCT) in bipolar disorder: preliminary evaluation of immediate effects on between-episode functioning. J Affect Disord. 2008 Apr; 107(1-3):275-9. | 3
328 | Williams JM, Russell IT, Crane C, et al. Staying well after depression: trial design and protocol. BMC Psychiatry. 2010;10:23. | 3
329 | Wingate LR, Van Orden KA, Joiner TE, Jr., Williams FM, Rudd MD. Comparison of compensation and capitalization models when treating suicidality in young adults. J Consult Clin Psychol. 2005 Aug;73(4):756-62. | 3
330 | Wohlfarth TD, van Zwieten BJ, Lekkerkerker FJ, et al. Antidepressants use in children and adolescents and the risk of suicide. Eur Neuropsychopharmacol. 2006 Feb;16(2):79-83. | 8
331 | Woldu H, Porta G, Goldstein T, et al. Pharmacokinetically and clinician-determined adherence to an antidepressant regimen and clinical outcome in the TORDIA trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2011 May;50(5):490-8. | 3
332 | Yerevanian BI, Koek RJ, Mintz J. Bipolar pharmacotherapy and suicidal behavior. Part I: Lithium, divalproex and carbamazepine. J Affect Disord. 2007 Nov;103(1-3):5-11. | 9
333 | Youssef NA, Rich CL. Does acute treatment with sedatives/hypnotics for anxiety in depressed patients affect suicide risk? A literature review. Annals of Clinical Psychiatry. 2008;20(3):157-69. | 7
334 | Zamorski MA. Suicide prevention in military organizations. Int Rev Psychiatry. 2011 Apr;23(2):173-80. | 7
335 | Ziemba KS, O'Carroll CB, Drazkowski JF, et al. Do antiepileptic drugs increase the risk of suicidality in adult patients with epilepsy?: a critically appraised topic. Neurologist. 2010 Sep;16(5):325-8. | 7
336 | Zisook S, Rush AJ, Lesser I, et al. Preadult onset vs. adult onset of major depressive disorder: a replication study. Acta Psychiatr Scand. 2007 Mar; 115(3): 196-205. | 9