# ABBREVIATIONS

Abbreviation: Term
AHRQ: Agency for Healthcare Research and Quality
CAMS: Collaborative Assessment and Management of Suicidality
CBT: Cognitive Behavioral Therapy
CI: Confidence interval
DBT: Dialectical Behavior Therapy
DoD: Department of Defense
DSM: Diagnostic and Statistical Manual of Mental Disorders
EBPWG: Evidence Based Practice Working Group
E-CAU: Enhanced Care As Usual
EPC: Evidence-based Practice Center
GRADE: Grading of Recommendations Assessment, Development, and Evaluation
HR: Hazard ratio
IMPACT: Improving Mood: Promoting Access to Collaborative Treatment
IRR: Incident Risk Ratio
ITT: Intention-to-treat
LOCF: Last Observation Carried Forward
MBT: Mentalization Based Treatment
N: Sample size
N/A: Not applicable
NDI: National Death Index
NICE: National Institute for Health and Clinical Excellence
OR: Odds ratio
PROSPECT: Prevention of Suicide in Primary Care Elderly: Collaborative Trial
PSA: Public Service Announcement
RCT: Randomized controlled trial
REACT: Randomized Evaluation of Assertive Community Treatment
RR: Relative risk
SCM: Structured Clinical Management
SD: Standard deviation
SSRI: Selective Serotonin Reuptake Inhibitor
STEPPS: Systems Training for Emotional Predictability and Problem Solving
SUD: Substance Use Disorder
TADS: Treatment for Adolescents With Depression Study
TBI: Traumatic Brain Injury
TORDIA: Treatment of SSRI-Resistant Depression in Adolescents
UK: United Kingdom
US: United States
VA: Veterans Affairs
VHA: Veterans Health Administration
YST: Youth-Nominated Support Team