# STRENGTH OF EVIDENCE RATINGS FOR PRIMARY STUDIES RELATED TO REFERRAL/FOLLOW-UP SERVICES^a^ a This review did not evaluate any outcomes other than suicidal self-directed violence, and therefore no additional data on potential harms and side effects was investigated. Potential harms and side effects should always be considered when evaluating the strength of evidence and considering adoption of an intervention or referral/followup service.

Table 1 Assertive Community Treatment

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Quality) | Consistency | Directness | Precision | Summary effect size (95% CI) | High, Moderate, Low, Insufficient
Assertive Community Treatment versus Community Mental Healthcare (Killaspy 2006)58
Suicide deaths
1; N=251 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 0.8% vs 2.5%, P NR | Low
Deliberate self-harm
1; N=251 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 8% vs 11%; P=0.40 | Low

Table 2 Case Management/Care Coordination

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Quality) | Consistency | Directness | Precision | Summary effect size (95% CI) | High, Moderate, Low, Insufficient
Depression Care Management versus Usual Care (Gallo 2007, Bogner 2007, Raue 2010; Prevention of Suicide in Primary Care Elderly: Collaborative Trial [PROSPECT])59, 128, 129
Suicide deaths, n/1000 person-years (95% CI)
1; N=599 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 0.7 (0.0 to 4.2) vs UC=0, 0.0 (0.0 to 3.3) | Low

Table 3 Emergency contact “green” card

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Quality) | Consistency | Directness | Precision | Summary effect size (95% CI) | High, Moderate, Low, Insufficient
Emergency contact “green” card versus Standard Care (Morgan 1993 as cited in Mann 2005)10
Suicide attempts
1; not reported | Medium (RCT/Unclear) | N/A | Indirect | N/A | Not reported | Insufficient to Low

Table 4 Postcard/Mailing Interventions

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Quality) | Consistency | Directness | Precision | Summary effect size (95% CI) | High, Moderate, Low, Insufficient
Postcard Intervention versus treatment as usual (Carter 2005/2007, Beautrais 2010)53-55
Proportion of patients with repeat deliberate self poisoning at 12 months and 24 months (Carter 2005/2007)54, 55
1; N=772 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 12 months: 15.1% vs 17.3%; -2% (95% CI, -7% to 3%) 24 months: 21.2% vs 22.8%; -1.7% (95% CI, -7.5 to 4.2 | Low
Cumulative number of repeat episodes of deliberate self poisoning at 12 months and 24 months (Carter 2005/2007)54, 55
1; N=772 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 12 months: IRR 0.55 (95% CI, 0.35 to 0.87) 24 months: 0.49 (95% CI, 0.33 to 0.73) | Low
Total proportions of patients re-presenting for self-harm at 12 months (Beautrais 2010)53
1; N=327 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | Adjusted OR=0.97 (95% CI, 0.58 to 1.62 | Low
Total number of self-harm re-presentations at 12 months (Beautrais 2010)53
1; N=327 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | Adjusted IRR=1.07 (95% CI, 0.80 to 1.43 | Low
Regular Mailings vs Standard Care (Motto 2001 as cited in Mann 2005)10
Suicide attempts
1; not reported | Medium (RCT/Unclear) | N/A | Indirect | N/A | Not reported | Insufficient to Low

Table 5 Youth-Nominated Support Team (YST) plus Treatment As Usual

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of rias (Design/Quality) | Consistency | Directness | Precision | Summary effect size (95% CI) | High, Moderate, Low, Insufficient
Youth-Nominated Support Team (YST) plus Treatment As Usual versus Treatment As Usual (King 2006, King 2009)56, 57
Suicide deaths
1; N=448 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 0.4% vs 0, P NR | Low
Proportion of adolescents with one or more suicide attempts
2; N=737 | Medium (RCT/Unclear) | Inconsistent | Indirect | Imprecise | YST-1: 17.3% vs 11.6%, P=0.26 YST-2: 13% vs 15%, P=0.51 | Low