# STUDY SELECTION FORM

## VA ESP Suicide Prevention Study Selection Process: Coding

### Step 1 Importing citations

- Enter database name, search date, and other details into Custom 1.

### Step 2 Title/Abstract level coding

- The objective of the title/abstract review phase is to eliminate obviously irrelevant publications. Abstracts that lack an explicit reference to suicidal self-directed violence (e.g., suicidally, behaviors, attempts, and suicides) will be excluded at this phase. Reviewers will provide decision and characteristic codes and these will be recorded in Custom 3 of the EndNote library.
  ○ [underlined: Decision codes]:
    ■ R=Retrieve
    ■ E=Exclude
    ■ B=Retrieve for Background
  ○ [underlined: Characteristic codes]: Our first priority is retrieval of systematic reviews, especially those focusing on Veteran/military populations. Our second priority is retrieval of primary studies in Veteran/military populations. For ease of identifying these subsets of publications in the ENL, reviewers should add either or both of the following codes when applicable:
    ■ SR=systematic review
    ■ V=Veteran and/or military population

### Step 3 Full-text level coding

- Record final decision to include study in review, and any other study characteristics of interest.
  ○ Characteristics of interest (recorded in Custom Fields):
    ■ Population: Veteran/Military or Non-Veteran/Military
    ■ Intervention Type: Psychotherapy, Pharmacotherapy, or Referral/Follow-up
    ■ Study Design: Systematic Review, clinical trial (randomized or nonrandomized), observational study, other
  ○ Full-text exclusion codes to be entered into Custom 4:
    ■ 1=Non-English language
    ■ 2=Ineligible country (only including US, UK, Canada, New Zealand, Australia)
    ■ 3=Ineligible outcome
    ■ 4=Ineligible intervention (i.e., broadly focused public health interventions implemented among populations, etc.)
    ■ 5=Study does not evaluate interventions
    ■ 6=Ineligible publication type (e.g., letter, editorial, publication available only as abstract, non-systematic review, etc.)
    ■ 7=Ineligible systematic review due to limitations in quality
    ■ 8=Nonsystematic regulatory agency analysis
    ■ 9=Non-RCT study design
- Full-text coding to be completed in the format of a label affixed to each publication in the format shown below. Reviewer 1 will circle relevant characteristics and inclusion decision, and list an exclusion code when applicable. Reviewer 2 will verify Reviewer 1's decisions and circle Agree or Disagree. All disagreements will be resolved using a consensus process and consensus decisions recorded.

Pop: Vet-Mil / Non-Vet-Mil

Intervention: Meds / Thpy / Ref-FU / NA

Design: SR / CT / Obs / Other

Rev1: Include / Exclude – Code: ____

Rev2: Agree / Disagree Consensus: ____