# STRENGTH OF EVIDENCE RATINGS FOR PRIMARY STUDIES RELATED TO PSYCHOTHERAPY^a^ a This review did not evaluate any outcomes other than suicidal self-directed violence, and therefore no additional data on potential harms and side effects was investigated. Potential harms and side effects should always be considered when evaluating the strength of evidence and considering adoption of an intervention or referral/followup service.

Table 1 Attached-Based Family Therapy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Attached-Based Family Therapy versus Enhanced Usual Care (Diamond 2010)46
Low lethality suicide attempts
1; 66 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | ABFT = 11% (4/35); EUC = 22% (7/31); p not reported | Low

Table 2 Cognitive and Cognitive Behavioral Therapies (CBT)

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Cognitive Therapy for suicide attempters versus Usual Care (Brown 2005 as cited in Mann 2005)10
Suicide re-attempt rate
1; not reported | Medium (RCT/Unclear) | N/A | Indirect | N/A | “Halved event rate” reported in Mann 2005 | Insufficient to Low
CBT for Cluster B Personality Disorders versus treatment as usual (Davidson 2010)41
Number of subjects with suicidal acts from 0-6 years
1; 106 | Low (RCT/Low) | N/A | Indirect | Imprecise | aOR = 0.37 (95% CI, 0.10 to 1.38) | Low
Mean episodes of suicidal acts from 0-6 years
1; 106 | Low (RCT/Low) | N/A | Indirect | Imprecise | aMD (TAU-CBT) = 1.26 (95% CI, -0.06 to 2.58) | Low
CBT versus Supportive Counseling (Tarrier 2006)51
Deaths by suicide after 18 months
1; 278 | High (RCT/High) | N/A | Indirect | Imprecise | CBT = 1; SC = 2; p not reported | Insufficient
CBT versus Problem Solving Therapy versus Usual Care (Stewart 2009)50 Repeated in Problem Solving Therapy table below
Average number of suicide attempts
1; 32 | High (RCT/High) | N/A | Indirect | Imprecise | CBT: 0.22 PST: 0.33 TAU: 0.22 No significant differences found for repetition of suicide attempts when PST group was compared to TAU | Insufficient

Table 3 Collaborative Assessment and Management of Suicidality (CAMS)

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
CAMS versus E-CAU (Comtois 2011)47
Mean number of suicide attempts and self-inflicted injuries at 12 months
1; 32 | High (RCT/High) | N/A | Indirect | Imprecise | Mean (SD): CAMS=1.2 (3.9) vs E-CAU=3.3 (7.6). P not reported. | Insufficient

Table 4 Dialectical Behavior Therapy (DBT)

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
DBT versus Community Treatment By Experts (Linehan 2006)38
Median suicides (interquartile range)
1; 111 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | DBT=0 (0 to 0) vs CTBE=0 (0 to 1) | Insufficient
Suicide attempts
1; 111 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | DBT=23.1% vs CTBE=46%, P=0.01, HR=2.66 (95% CI not reported; P=0.005), NNT=4.24 (95% CI, 2.40 to 18.07) | Low
DBT versus Standard Care (Hawton 2000 as cited in Mann 2005)10
Unclear outcome reported in Mann 2005
1 systematic review; not reported | Medium (SR/Unclear) | N/A | Indirect | N/A | Not reported | Insufficient to Low
DBT versus General Psychiatric Management (McMain 2009)42
Deaths by suicide
1; 180 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | No events | Insufficient
Mean number of suicidal and self-injurious episodes at 12 months
1; 180 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | DBT=4.29 (9.32) vs GPM=12.87 (51.45); OR 0.92 (P=0.76) | Low

Table 5 Group Therapy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Group Therapy versus Routine Care (Hazell 2009)49
Repetition of Deliberate Self-Harm by 6 months
1; 72 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | GT = 88% (30/34); RC = 68% (23/34); p = 0.04 | Low
Repetition of Deliberate Self-Harm in interval of 6 to 12 months
1; 72 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | GT = 88% (30/34); RC = 71% (24/34); p = 0.07 | Low
Group Therapy versus Routine Care (Green 2011)44
Self-harm resulting in severe physical injury at 12 months
1; 366 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | Group therapy: 1/183 Usual care: 2/183 P not reported | Low
Suicide death at 12 months
1; 366 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | No events | Low

Table 6 IMPACT intervention

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
IMPACT intervention versus Usual Care (Unutzer 2006)52
Deaths by suicide after 24 months
1; 1801 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | No events | Insufficient

Table 7 Intensive Care Plus Outreach

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Intensive Care Plus Outreach versus Standard Care (Hawton 2000 as cited in Mann 2005)10
Unclear outcome reported in Mann 2005
1 systematic review; not reported | Medium (SR/Unclear) | N/A | Indirect | N/A | Not reported | Insufficient to Low

Table 8 Intensive Case Management

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Summary effect size (95% CI) | High, Moderate, Low, Insufficient
Intensive Case Management versus Treatment as Usual (De Leo 2007)45
Suicide at 12 months
1; 22 | High (RCT/High) | N/A | Indirect | Imprecise | No suicides in either group | Insufficient
Self-harming behavior at 6 months
1; 22 | High (RCT/High) | N/A | Indirect | Imprecise | Intensive case management: 3/14 (21.4%) Treatment as usual: 1/8 (12.4%) 12 months: | Insufficient
Self-harming behavior at 12 months
1; 22 | High (RCT/High) | N/A | Indirect | Imprecise | Intensive case management: 2/14 (14.3%) Treatment as usual: 2/8 (25.0%) | Insufficient

Table 9 Interpersonal Psychotherapy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Interpersonal Psychotherapy versus Standard Care (Guthrie 2001 as cited in Mann 2005)10
Unclear outcome reported in Mann 2005
1; not reported | Medium (RCT/Unclear) | N/A | Indirect | N/A | Not reported | Insufficient to Low

Table 10 Mentalization Based Treatment (MBT)

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
MBT versus treatment as usual (Bateman 2008)
Any suicide attempt
1; 41 | High (RCT/High) | N/A | Indirect | Imprecise | d=2.0 (95% CI, 1.4 to 4.9) | Insufficient
Mean total suicide attempts
1; 41 | High (RCT/High) | N/A | Indirect | Imprecise | d=1.4 (95% CI, 1.3 to 1.5) | Insufficient
MBT versus Structured Clinical Management (SCM) (Bateman 2009)37
Life-threatening suicide attempts, proportion with episode at end of treatment
1; 134 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | d=0.65 (95% CI, 0.58 to 0.73) | Low
Severe self-harm incidents, proportion with episode at end of treatment
1; 134 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | d=0.62 (95% CI, 0.28 to 0.97) | Low

Table 11 Personal Construct Psychotherapy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Personal Construct Psychotherapy versus Normal Clinical Practice (Winter 2007)43
Deaths by suicide after 5 years
1; 40 | High (RCT/High) | N/A | Indirect | Imprecise | PCP = 1; NCP = 2; p not reported | Insufficient
Repetition of deliberate self-harm after 5 years
1; 40 | High (RCT/High) | N/A | Indirect | Imprecise | 39% vs 58% (P=0.15) | Insufficient

Table 12 Problem-Solving Therapy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Problem-Solving Therapy plus treatment as usual versus treatment as usual (Hatcher 2011)36
Participants re-presenting to hospital for self-harm: All consenting patients
1; 552 | Low (RCT/Low) | N/A | Indirect | Imprecise | RR= 0.17 (95% CI -0.24 to 0.44); P=0.43 | Moderate
Participants with self-reported self-harm: All consenting patients
1; 412 | Low (RCT/Low) | N/A | Indirect | Imprecise | RR= 0.16 (95% CI -0.13 to 0.38); P=0.29 | Moderate
Time to re-presentation to hospital for self-harm: All consenting patients
1; 139 | Low (RCT/Low) | N/A | Indirect | Imprecise | HR= 0.81 (95% CI 0.53 to 1.25); P=0.92 | Moderate
Participants re-presenting to hospital for self-harm: Consenting patients; first episode of self-harm hospitalization is index episode
1; 306 | Low (RCT/Low) | N/A | Indirect | Imprecise | RR= -0.56 (95% CI -1.96 to 0.18); P=0.23 | Moderate
Participants with self-reported self-harm: Consenting patients; first episode of self-harm hospitalization is index episode
1; 220 | Low (RCT/Low) | N/A | Indirect | Imprecise | RR= -0.25 (95% CI -1.03 to 0.24); P=0.47 | Moderate
Time to re-presentation to hospital for self-harm: Consenting patients; first episode of self-harm hospitalization is index episode
1; 137 | Low (RCT/Low) | N/A | Indirect | Imprecise | HR= 1.62 (95% CI 0.82 to 3.18); P=0.16 | Moderate
Participants re-presenting to hospital for self-harm: Consenting patients; repeat episode of self-harm hospitalization is index episode
1; 246 | Low (RCT/Low) | N/A | Indirect | Imprecise | RR= 0.47 (95% CI 0.11 to 0.69); P=0.02; NNT=8 | Moderate
Participants with self-reported self-harm: Consenting patients; repeat episode of self-harm hospitalization is index episode
1; 192 | Low (RCT/Low) | N/A | Indirect | Imprecise | RR= 0.37 (95% CI 0.08 to 0.57); P=0.02; NNT=6 | Moderate
Time to re-presentation to hospital for self-harm: Consenting patients; repeat episode of self-harm hospitalization is index episode
1; 149 | Low (RCT/Low) | N/A | Indirect | Imprecise | HR= 0.47 (95% CI 0.26 to 0.85); P=0.01 | Moderate
Participants re-presenting to hospital for self-harm: All patients
1; 1094 | Low (RCT/Low) | N/A | Indirect | Imprecise | RR= 0.05 (95% CI -0.28 to 0.30); P=0.79 | Moderate
Time to re-presentation to hospital for self-harm: All patients
1; 149 | Low (RCT/Low) | N/A | Indirect | Imprecise | HR= 0.98 (95% CI 0.71 to 1.36); P=0.92 | Moderate
Participants re-presenting to hospital for self-harm: All patients; first episode of self-harm hospitalization is index episode
1; 674 | Low (RCT/Low) | N/A | Indirect | Imprecise | RR= 0.42 (95% CI -1.17 to 0.08); P=0.37 | Moderate
Time to re-presentation to hospital for self-harm: All patients; first episode of self-harm hospitalization is index episode
1; 135 | Low (RCT/Low) | N/A | Indirect | Imprecise | HR= 1.55 (95% CI 0.98 to 2.48); P=0.06 | Moderate
Participants re-presenting to hospital for self-harm: All patients; repeat episode of self-harm hospitalization is index episode
1; 420 | Low (RCT/Low) | N/A | Indirect | Imprecise | RR= 0.39 (95% CI 0.07 to 0.60); P=0.03; NNT=12 | Moderate
Time to re-presentation to hospital for self-harm: All patients; repeat episode of self-harm hospitalization is index episode
1; 194 | Low (RCT/Low) | N/A | Indirect | Imprecise | HR= 0.58 (95% CI 0.36 to 0.94); P=0.03 | Moderate
Problem-Solving Therapy versus Standard Care (Hawton 2000 as cited in Mann 2005)10
Unclear outcome reported in Mann 2005
1 systematic review; not reported | Medium (SR/Unclear) | N/A | Indirect | N/A | Not reported | Insufficient to Low
CBT vs Problem Solving Therapy vs Usual Care (Stewart 2009)50 Repeated in Cognitive Therapy table above
Average number of suicide attempts
1; 32 | High (RCT/High) | N/A | Indirect | Imprecise | CBT: 0.22 PST: 0.33 TAU: 0.22 No significant differences found for repetition of suicide attempts when PST group was compared to TAU | Insufficient

Table 13 Psychoanalytically Oriented Partial Hospitalization

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Psychoanalytically Oriented Partial Hospitalization versus Standard Care in patients with Borderline Personality Disorder (Bateman 2001 as cited in Mann 2005)10
Unclear outcome reported in Mann 2005
1; not reported | Medium (RCT/Unclear) | N/A | Indirect | N/A | Not reported | Insufficient to Low

Table 14 Skills Based Treatment

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Skills Based Treatment versus Supportive Relationship Treatment (Donaldson 2005)48
Number of re-attempts at 6 months
1; 39 | High (RCT/High) | N/A | Indirect | Imprecise | SBT=26.7% (4/15) vs SRT=12.5% (2/16); χ^2^=1.00 | Insufficient

Table 15 Systems Training for Emotional Predictability and Problem Solving (STEPPS)

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Systems Training for Emotional Predictability and Problem Solving versus treatment as usual (Blum 2008)39
Time to first suicide attempt
1; 165 | High (RCT/High) | N/A | Indirect | Imprecise | χ^2^<0.1, df=1, p=0.994 | Low
Time to first self-harm act
1; 165 | High (RCT/High) | N/A | Indirect | Imprecise | χ^2^<0.1, df=1, p=0.902 | Low