# STRENGTH OF EVIDENCE RATINGS FOR PRIMARY STUDIES RELATED TO PHARMACOTHERAPY^a^ a This review did not evaluate any outcomes other than suicidal self-directed violence and, therefore, no additional data on potential harms and side effects was investigated. Potential harms and side effects should always be considered when evaluating the strength of evidence and considering adoption of an intervention or referral/follow-up service.

Table 1 Antidepressants vs placebo

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/ Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Escitalopram versus placebo (Emslie 2009, Wagner 2006)20, 22
Suicide deaths (Wagner 2006)22
1; 268 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | No events | Insufficient
Adverse events suggestive of self-harm, with a suicidal tendency (Emslie 2009)20
1; 316 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 0 vs 0.6% (1/157) | Low
Fluoxetine versus placebo (TADS)19, 21, 124, 125
Suicide deaths at 36 weeks
1; 221 | Low (RCT/Low) | N/A | Indirect | Imprecise | No events | Insufficient
Suicide attempts at 36 weeks
1; 221 | Low (RCT/Low) | N/A | Indirect | Imprecise | 6.4% (7/109) vs 5.4% (6/112), P not reported | Low
Paroxetine versus placebo (DeRubeis 2005, Emslie 2006)18, 23
Suicide deaths (DeRubeis 2005)23
1; 180 | Low (RCT/Low) | N/A | Indirect | Imprecise | 0.8% (1/120) vs 0 | Low
Suicide behavior (Emslie 2006)18
1; 206 | Low (RCT/Low) | N/A | Indirect | Imprecise | 2% (2/104) vs 0 | Low

Table 2 Antidepressants vs antidepressants

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/ Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Escitalopram plus placebo vs escitalopram plus bupropion SR vs venlafaxine XR plus mirtazapine (Zisook 2011)25
Suicide deaths
1; 665 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | No events | Insufficient
Suicide attempts
1; 665 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 0 vs 0 vs 2.3%, P=0.0162 | Low
Bupropion vs paroxetine (Grunebaum 2011)24
Suicide deaths
1; 78 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | No events | Insufficient

Table 3 Antidepressants alone vs antidepressants plus Cognitive Behavioral Therapy (CBT)

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/ Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Fluoxetine alone vs fluoxetine plus CBT (TADS)19, 21, 124, 125
Suicide deaths at 36 weeks
1; 216 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | No events | Insufficient
Suicide attempts at 36 weeks
1; 216 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 6.4% vs 3.7%, P not reported | Low
Switch to another SSRI or venlafaxine, with or without CBT (TORDIA)26, 126
Suicidal self-injury adverse events at 12 weeks
1; 334 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | No statistically significant treatment effects (rates NR) | Low
SSRI alone (fluoxetine treatment of choice) vs SSRI plus CBT (ADAPT)27
Suicide acts at 28 weeks
1;208 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 6.4% vs 7.1% | Low

Table 4 Antidepressants versus Cognitive Behavioral Therapy (CBT)

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/ Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Antidepressants versus CBT (DeRubeis 2005)23
Suicide deaths
1; 180 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 0.8% vs 0 | Low

Table 5 Atypical Antipsychotics

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/ Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Quetiapine (Calabrese 2005)28
Suicide attempts
1; 542 | Low (RCT/Low) | N/A | Indirect | Imprecise | 0.5% (1/180) vs 0.5% (1/181) vs 0, P-value NR | Low
Suicides
1; 542 | Low (RCT/Low) | N/A | Indirect | Imprecise | No events | Low
Aripiprazole (Berman 2007, Marcus 2008)29, 30
Suicides
2; 743 | Medium (RCT/Unclear) | Consistent | Indirect | Imprecise | No events | Low
Clozapine (Glick 2004 & Meltzer 2003 as cited in Mann 2005)10
Unclear outcome in Mann 2005^10^
2; not reported | Medium (RCT/Unclear due to lack of report) | Consistent | Indirect | N/A | Not reported | Insufficient to Low

Table 6 Mood stabilizers

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; # of subjects | Risk of bias (Design/ Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Lithium versus valproate (Oquendo 2011)32
Suicide deaths
1; 98 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | No events | Insufficient
Suicide attempts
1; 98 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | 12% (6/49) vs 16% (8/49) | Low
Time to suicide attempt
1; 98 | Medium (RCT/Unclear) | N/A | Indirect | Imprecise | Log-rank test showed no differences | Low
Citalopram plus lithium versus citalopram plus placebo (Khan 2011)33
Suicide deaths
1; 80 | Low (RCT/Low) | N/A | Indirect | Imprecise | No events | Insufficient
Suicide attempts
1; 98 | Low (RCT/Low) | N/A | Indirect | Imprecise | No events | Insufficient
Lithium versus placebo (Lauterbach 2008)34
Suicide deaths
1; 167 | High (RCT/High) | N/A | Indirect | Imprecise | 0% (0/84) 3.6% (3/83) Incidence rate per patient-year: 0% vs 6.5% P=0.049 | Insufficient
Suicide attempts
1; 167 | High (RCT/High) | N/A | Indirect | Imprecise | 8.3% (7/84) 8.4% (7/83) Not significant | Insufficient
Composite of suicide attempt/suicide death
1; 167 | High (RCT/High) | N/A | Indirect | Imprecise | Adjusted HR: 0.52 (0.19 to 1.44); P=0.206 | Insufficient
Lithium (Theis-Flechtner 1996 as cited in Mann 2005)10
Unclear outcome in Mann 2005
1; not reported | Medium (RCT/ Unclear due to lack of report) | N/A | Indirect | N/A | Not reported | Insufficient to Low

Table 7 Omega-3 fatty acid supplementation vs placebo (Hallahan 2007)35

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; #of subjects | Risk of bias (Design/ Risk of bias) | Consistency | Directness | Precision | Magnitude of effect | High, Moderate, Low, Insufficient
Suicide deaths
1; 49 | Low (RCT/Low) | N/A | Indirect | Imprecise | No events | Insufficient