# SEARCH STRATEGIES

PubMed searched from 2005 – November 18, 2011

Suicide | “Suicide”[Mesh] OR “Suicide, Attempted”[Mesh] OR suicid*
Risk | “Risk”[Mesh] OR “Risk Assessment”[Mesh] OR “Risk Factors”[Mesh] OR risk[Title/Abstract]
Screening | “mass screening”[Mesh] OR “Validation studies”[Publication Type] OR Screening[title] OR screen[title] OR assessment[title] OR assessments[title] OR questionnaire[title] OR questionnaires[title] OR instrument[title] OR instruments[title] OR tool[title] OR tools[title] OR scale[title] OR scales[title] OR measure[title] OR measures[title]
Prevention | Prevent* OR depression OR health education OR health promotion OR public opinion OR mass screening OR family physicians OR medical Education OR primary healthcare OR antidepressive agents OR psychotherapy OR schools OR adolescents OR methods OR firearms OR overdose OR poisoning OR gas poisoning OR mass media
Suicide Prevention | (“Suicide/prevention and control”[Mesh] OR Suicide, Attempted/ prevention and contril”[Mesh]) NOT (case report* OR editorial* OR letter)
Suicide Prevention OR (Suicide AND (Risk OR Screening OR Prevention)

PsycINFO, Cochrane and HAPI Search November 18, 2011 Limited from 2005 – November 18, 2011 Search Strategy
1. exp Attempted Suicide/ or exp Suicide Prevention/
2. (prevent* or depression or health education or health promotion or public opinion or mass screening or family physicians or medical education or primary health care or antidepressive agents or psychotherapy or schools or adolescents or methods or firearms or overdose or poisoning or gas poisoning or mass media).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
3. suicide.mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
4. 2 and 3
5. 1 or 4
6. exp Case Report/
7. editorial.mp.
8. letter.mp.
9. 6 or 7 or 8
10. 5 not 9
11. exp Attempted Suicide/ or exp Suicide/ or suicide.mp.
12. (suicide or suicidal or suicides or sucidality).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
13. 11 or 12
14. exp Risk Assessment/ or risk.mp. or exp Risk Factors/
15. exp Screening/
16. exp test validity/
17. screening.m_titl.
18. screen.m_titl.
19. assessment.m_titl.
20. assessments.m_titl.
21. questionnaire.m_titl.
22. questionnaires.m_titl.
23. instrument.m_titl.
24. instruments.m_titl.
25. tool.m_titl.
26. tools.m_titl.
27. scales.m_titl.
28. measure.m_titl.
29. measures.m_titl.
30. risk.mp.
31. 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30
32. 13 and 31
33. 10 or 32