# SUMMARY AND DISCUSSION

In this chapter, we describe the limitations of our review and then present our conclusions. We also discuss the implications of our findings for future research.

## LIMITATIONS

### PUBLICATION BIAS

Our literature search procedures were extensive. It was not possible to conduct formal tests for publication bias, but even with such tests it is not possible to exclude the possibility that such bias exists. Therefore, readers are cautioned about this possibility.

### STUDY QUALITY

An important limitation common to systematic reviews is the quality of the original studies. Recent attempts to define elements of study design and execution that are related to bias have shown that in many cases, such efforts are not reproducible and do not distinguish study results based on bias. Therefore, the current approach is to avoid rejecting studies or using quality criteria to adjust the results of the review. We did use the Delphi list criteria as a descriptive measure of quality.11 As there is a lack of empirical evidence regarding study characteristics and their relationship to bias, we did not attempt to use other criteria. Other aspects of the design and execution of a trial may be related to bias, but we do not yet have good measures of these elements. Because of the small number of studies found, it was not possible to do sensitivity analyses based on study quality.

### HETEROGENEITY

Clearly, the populations being assessed were different, and there were also important differences in how some key variables were measured, characteristics of the interventions, and outcomes measured, among others. This heterogeneity further limits our ability to draw strong conclusions.

### APPLICABILITY OF FINDINGS

Green & Glasgow87 provide a framework for evaluating the relevance, generalization, and applicability of research. Their framework includes assessing the participation rate, the intended target population, the representativeness of the setting, the representativeness of the individuals, and evaluating information about implementation and assessment of outcomes. As these data are rarely reported in the studies we reviewed, conclusions about applicability are necessarily weak.

### COMPARISON WITH SYSTEMATIC REVIEWS AND META-ANALYSES

We now discuss how our results relate to those published in other, similar systematic reviews and meta-analyses.

Gaynes et al.7 presented a systematic review for the US Preventive Services Task Force on screening for suicide risk in adults with a focus on primary care settings. They found “extremely limited” evidence that could be used for assessment and management of the risk of suicide by primary care clinicians. “No studies address the overarching question of whether screening for suicide risk in primary care patients improves outcome…. Regarding whether interventions for those at risk reduce suicide attempts or completions, the poor generalizability of the studies makes the overall strength of evidence fair, at best, while the results are mixed. Although some trends suggest incremental benefit from several interventions, no consistent statistically significant effects have emerged for interventions for which more than 1 study has been done.”

Mann et al.1 whose conceptual model and results guided the construction of our review, concluded that “the most promising interventions are physician education, means restriction, and gatekeeper education.” However their conclusion about physician education was based on studies in countries (Hungary, Japan, and the island of Gotland, Sweden) whose suicide rates and patterns are not similar to those in the US population. The gatekeeper education result followed from a single study, the multifaceted USAF suicide prevention program, which actually provided significantly more services than just gatekeeping.

Morgan and Majeed88 reviewed the UK studies on paracetamol restriction, and found some evidence for a decrease in admission to liver units and transplant requests after the introduction of the restrictions. However, they noted as complicating factors small sample sizes, the lack of a precise definition of paracetamol poisoning, and the absence of any control groups in the studies examined. They also observed that in spite of the restrictions, paracetamol was still commonly used as a means of suicide.

Hawton et al.89 conducted a review for the Cochrane Collaboration on psychosocial and pharmacological treatments for deliberate self-harm. They found non-significant trends for problem-solving therapy, provision of an emergency contact card, intensive aftercare plus outreach, and antidepressant treatment. They concluded that “considerable uncertainty” remained, and that the clinical trials reviewed to date had been too small.

Crawford et al.90 reported a systematic review of RCTs for psychosocial interventions following episodes of self-harm, and for 18 studies found no difference in the suicide rate between treatment and control groups. Three of the studies involved children or adolescents. Crawford et al. also included psychotherapeutic interventions – none of which were included in our review. Sample size and lack of statistical power were identified as complicating factors. They argued for pursuing public health approaches, such as means restriction and media guidelines for reporting.

#### Other non-systematic reviews

One non-systematic review relevant to our report was identified. Lester91 reviewed the evidence supporting the use of suicide prevention centers. Fourteen independent studies were identified, of which seven showed evidence for protective effects, but these were not consistent across gender, age groups, and suicide methods. When protective effects were found, they were often small in magnitude. Lester combined the studies using a meta-analysis, which did achieve statistical significance, with a correlation coefficient of −0.16 (which is equivalent to an effect size of −0.32).

#### Reviews of mental health interventions

Our review did not focus on purely mental health interventions. These have been the subject of other reviews. Perhaps somewhat surprisingly given the role of depressive disorders as significant risk factors for suicide, the evidence in support of the use of antidepressants is rather weak. Isaacson and Rich92 in nonsystematic review on the protective effects of antidepressants for suicide concluded, in part, “Pooled data from controlled clinical trials of antidepressants have not demonstrated a suicide preventive effect, but patient selection and the brief time of most trials limits the power of the data. Some reports from either long-term or very large databases have provided evidence that antidepressants prevent suicide.”(p153)

Some of the best evidence for psychopharmacologic interventions that reduce suicide risk is for lithium in the treatment of bipolar disorder. Baldessarini et al.93 reported a meta-analysis of 31 published studies that showed a robust protective effect of lithium for both completed and attempted suicides for both bipolar disorder and other mood disorders. There is also some evidence supporting the use of the antipsychotic clozapine to reduce suicide attempts in schizophrenia. Further details appear in a non-systematic review by Hennen and Baldessarini94 and a systematic review by Aguilar and Siris.95

## CONCLUSIONS

With the above limitations in mind, we reached the conclusions displayed below.

### KEY QUESTION #1: What are the new or improved suicide prevention strategies (e.g., hotlines, outreach programs, peer counseling, treatment coordination programs, and new counseling approaches) that show promise for Veterans?

### KEY QUESTION #2: What solid evidence base supports the most promising strategies?

Multicomponent interventions in military personnel probably reduce the risk of suicide. The largest and best described such study is by Knox, and this article provides the most convincing evidence of effectiveness. The report of success of a program in Yugoslavia modeled after the Knox program increases our confidence that the effect is real. A similar program was developed for the US Navy and Marine Corps. However, as with any multicomponent intervention shown to be successful, there are still numerous questions about the relative merit of inclusion of each individual component (could the same effect be achieved with fewer components?) or the possible increase in effectiveness of adding other components, and optimizing the effectiveness of each additional component. Additionally, there are no data about its effect in non-military populations, although veterans would seem to be sufficiently close to a military population that some transferability of results could be assumed. (GRADE quality of evidence = Low, meaning further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate)

There are insufficient studies of suicide prevention programs specifically in veterans to draw conclusions (GRADE quality of evidence = Very Low, meaning any estimate of effect is uncertain)

Psychosocial interventions following a suicide attempt are, at the very best, only minimally effective (GRADE quality of evidence = Moderate, meaning further research is likely to have an important impact on our confidence in the estimate of the effect and may change the estimate).

There are insufficient data to reach conclusions about Community-based Suicide Prevention Centers (GRADE quality of evidence = Very Low, meaning any estimate of effect is uncertain)

We found no studies that assessed the specific effectiveness of any of hotlines, outreach programs as primary prevention interventions, peer counseling, treatment coordination programs, and new counseling programs.

Restriction of access to lethal means probably has an effect on cause-specific suicides, although its effect on total suicides is less clear (GRADE quality of evidence = Low, meaning further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate)

### KEY QUESTION #3: What evidence is still needed to establish various strategies as the most promising (framed as research questions to guide and focus continued research to expand knowledge regarding the effectiveness of suicide prevention approaches)?

Multifaceted interventions are supported by consistent evidence, although of very mixed quality. Even if such programs are later determined to be robustly successful, the question of which components in those programs are causally related to the reduction in suicides has not been addressed. This sets as a research issue determining which components work best in which combinations for which populations. The issue of whether some sets of components may have facilitative or synergistic effects has not been addressed.

Psychosocial intervention for suicide attempters have considerable face validity as they address a group with manifest evidence of suicide risk, but there is no consistent evidence in their support in spite of a moderate number of randomized controlled trials that been conducted. This is an area of obvious and considerable interest to the VA, which is now using similar approaches in its clinical programs to identify and track those at high risk with suicide risk flags, screening tools, and suicide prevention coordinators. An additional factor that seems relevant but rarely directly studied is the effect of forming a consistent relationship with a single provider, a therapeutic alliance, and its role in providing a protective degree of social connection, and reducing the harmful consequences of social isolation.

Further randomized controlled trials and high-quality observational studies are definitely needed. Without waiting for such to be completed, and independent of which program components the VA decides to pursue, there are two supporting initiatives that could be implemented in parallel. The first concerns standardizing vocabulary, and the second concerns electronic medical records.

First, all suicide prevention programs are dependent on the accuracy with which assessments of suicidality are conducted. The term “suicide attempt” covers a very broad array of self-injurious behaviors, from intentionally planned, high lethality events that were interrupted by mere happenstance, through low lethality acts marked by a small risk of physical harm, impulsivity, and a high likelihood of discovery by others. Others have noted the importance of establishing and using a consistent nomenclature in this area.96 It is critical for further advances in suicide reduction that such attempts are carried through.

A very important reason for accurately describing the severity of suicide attempts is that an attempt is widely recognized as a significant risk factor for completions. Although most completed suicides are first attempts2 and attempters vary in important ways from completers,3 it is known that survivors of highly lethal attempts have similar clinical and psychosocial profiles to antemorten profiles of suicide completers. This suggests that subcategorization of attempt by lethality (or perhaps other factors) may be clinically useful.

Completed suicides are thought to be more easily determined, as they are judged such on the basis of a coroner or medical examiner ruling. In most cases the determination is straightforward, but others, such as single-occupant car crashes, raise the issue of disguised suicides, where intent may have been willfully hidden for reasons of shame or insurance coverage. Crawford et al.90 noted difficulties in using reported suicides because of problems of ascertainment. Addressing these forensic issues is mostly outside the purview of the VA.

Second, because the VA uses a single, integrated computerized medical record system for all of its clinical activities, any improvements in vocabulary along with new screening and tracking tools would allow for data gathering as part of routine practice – especially for establishing patterns and risk factors for suicide attempts – in advance of formally conducted observational studies or controlled trials.