# RESULTS

## LITERATURE FLOW – UPDATE

In total, we examined 3,406 titles. The electronic literature search identified 3,212 articles. An additional 196 articles were identified through reference mining. A content expert identified 5 more articles.

Of the titles identified through our electronic literature search, 3,140 were rejected at title review as clearly irrelevant to the project. This left 273 from all sources. Seven articles were rejected as not relevant. Five titles could not be located after contacting many sources. (Figure 2)

Figure 2 Literature Flow

We reviewed a total of 261 articles. Initial screening of the articles resulted in three articles that included veterans and seven articles that included military personnel. We excluded 135 article for the following reasons: five because they did not include an intervention, two foreign language articles, three articles contained duplicate data, 41 review or meta-analyses, 82 articles with no outcome of interest or no usable data, one study of adolescents only, and one editorial. This left 126 articles included for further review.

Following guidance from the ESP Advisory Committee in our further inclusion criteria we excluded an additional 49 studies. Studies were excluded for studies conducted in countries other than US, Canada, United Kingdom, Ireland, Australia, or New Zealand and not containing military personnel or veterans; only reporting suicidal ideations, or being a strictly psychotherapy or pharmacotherapy study. Of studies that met our inclusion criteria we found 20 RCT or CCT studies, 28 observational studies, 6 cohort studies, and 23 interrupted time series studies.

Excluded articles and reasons for exclusion are listed in Appendix B.

The results have been grouped together by the kind of intervention, and within that, by study design. We first report on studies of military or veterans that use multifaceted (multi-component) interventions. This includes all the studies (of any type) that directly studied military personnel. For comparison, we then present other multifaceted interventions, both of which are national suicide prevention programs. We then report on several other interventions identified that included veterans.

## KEY QUESTION #1: What are the new or improved suicide prevention strategies (e.g. hotlines, outreach programs, peer counseling, treatment coordination programs, and new counseling approaches) that show promise for Veterans?

## KEY QUESTION #2: What solid evidence base supports the most promising strategies?

### OVERVIEW

This results section is organized by the target and the method of the intervention, first with studies of multifaceted interventions. We found studies of multifaceted interventions only for military personnel or the general population. We did not find any studies of multifaceted interventions for veterans. Following the review of multifaceted interventions is a review of the studies that did include veterans. The report then discusses evidence from other populations using interventions post-suicide attempt, suicide prevention centers, hospital admission for attempted suicide, collaborative care for depression, and an intervention for the identified patient’s support network. Then observational studies for restricting access to lethal means (firearms, acetaminophen, other toxic agents, and bridge barriers), and restrictions of media reporting of suicides are presented.

#### Multifaceted interventions for military personnel

Seven studies involving military personnel were identified. All were prospective cohort studies in which the intervention was implemented for the entire population. The characteristics, interventions, and outcomes of the military studies are shown in Evidence Table 1 in Appendix C.

James and Kowalski13 described a suicide prevention program for the US Army 25^th^ Infantry Division (Light) that was started in 1992 and fully implemented by early 1994. Psychological autopsy data from 1985 to 1993 identified various risk factors in this population including demographics (all male), mental status (depression), substance abuse, and relationship problems (all the suicides involved marital or relationship discord or alleged infidelity).The intervention reported was multifactorial and multidisciplinary. The disciplines involved included the chaplain (to provide individual counseling and division-wide education), the psychologist (to coordinate training, and assist in identifying high-risk soldiers), the social worker (to provide a liaison for the soldier, their family, and the soldier’s commander). Specific components of the intervention as reported included: lectures by chaplains, lectures at training programs (for division commanders and enlisted soldiers), pocket-sized cards with warning signs and contact information for emergency services, “crisis-intervention command consultations” (special meetings with soldier, their commanders, and division mental health officer), a “high-risk book” (once identified as high risk, the soldier’s commander provide bi-monthly written assessments on the soldier’s progress), outpatient follow up care with mental health services, and mental health services for the soldier and their family, along with a substance abuse prevention program. The size of the study population was not reported. The program was not formally evaluated, but in a postscript the authors noted, “the suicide rate has decreased to three in the past 2 years.” Unfortunately, the baseline comparison rate was not clearly reported, so we cannot reach any conclusions about effectiveness.

McDaniel et al.14 reported on a suicide prevention program at a US Navy Training Command that was implemented after a cluster of suicides in 1986. The target of the intervention was the petty officers and chief petty officers who were the instructors at the command. They were educated to recognize risk factors likely to be common in the students of the training command (recent interpersonal losses, substance abuse, social isolation, and personality disorders and psychiatric illnesses), and about the goals of fostering group cohesiveness and ensuring treatment compliance for those referred for treatment. The size of the study population was not reported. The main outcome assessed was suicide attempts at the training command in comparison with that reported at a similarly sized operational command nearby. They reported a statistically significant negative correlation between the number of instructors trained and the number of suicide attempts. They concluded that the program reduced the number of suicide attempts at the training command. However, there were a number of complicating factors, including seasonal factors stemming for start dates for cohorts of students at the training command and limited of hours of operation when potentially suicidal students were referred to the operational command for evaluation (thus inflating the number of suicide attempts reported at the latter facility).

Knox et al.15 described a multifactorial suicide prevention program implemented in the US Air Force, comprising over 5,000,000 active duty personnel. The intervention was designed to reduce stigma and risk factors, and strengthen protective factors in a population-based approach. The program had 11 components. There was training for squadron commanders, addition of suicide prevention into required training, use of guidelines for mental health referral, addition of staff to support community-based preventive services at mental health centers, and required training for non-professionals in suicide risks and referral procedures. The program also assessed for suicide risk those under investigation for legal problems, established teams to respond to traumatic events including suicides, integrated the delivery system for human services prevention activities, established patient privilege in psychotherapy, conducted a behavior health survey, and established a suicide event surveillance system for tracking risk factors. To evaluate the program, the USAF population from 1990–6 was the control cohort, and the 1997–2002 population was the treatment cohort. No differences in demographic characteristics or in rates for mental health disability were found between the two groups. There was a statistically significant trend for decline in suicide rate over time, with a 33% reduction of risk for completed suicide compared to the baseline rate. The average rate in the pre-intervention period was 13.5 per 100,000, and 9.2 in the post-intervention period.

Jones et al.16 described a US Navy and Marine Corps initiative to reducing suicide using “best practice strategies.” They identified existing resources relevant to suicide prevention, which included awareness (education about suicide prevention for all personnel and in leadership schools), life skills training (for substance abuse, stress and anger management, conflict resolution), post-suicide attempt interventions (family support, critical event stress debriefing), and data collection (suicide incident reports with explicit monitoring and tracking of data). A training video on suicide prevention was developed for all personnel; it highlighted positive role models and early identification of those at risk by co-workers, and was included as part of the required annual General Military Training (GMT) starting in the summer of 2000. The size of the study population was not reported. The authors reported that, “the introduction of annual suicide prevention GMT requirement coincided with a drop in Navy suicide rate for FY-01 to 9.2/100K. This is the lowest rate in 10 years.” The Marine Corps rate for the same year was 15.6/100,000, but no baseline rate or comparison was provided.

Kennedy et al.17 described an overseas gambling treatment program for the US Navy. Pathological gambling was recognized to have significant psychiatric comorbidity, including substance abuse, mood disorders, and suicidality. The program focused on overseas gambling because of the relative lack of restriction on slot machines in military clubs overseas, and the lack of overseas treatment options for pathological gambling. The services were provided at a naval base in Okinawa, Japan within the context of a substance abuse rehabilitation program, and included psychological evaluation, individual and group counseling, patient and family education, Gambler’s Anonymous, and access to a gambling crisis counseling around the clock. The program was evaluated for a year (roughly, the calendar year 2004) during which 35 individuals were referred. Twenty percent of those reported suicidal ideation, and 3 had made gambling-related suicide attempts before referral. During the treatment period, there were no attempted suicides and no suicidal ideation recurred.

Two suicide military-based suicide prevention programs outside the US have been reported. Rozanov et al.18 described a program implemented in a military unit of size 10,000 in the Ukrainian Army. The program set up training seminars about suicide, risk factors, and prevention for commanders, officers, and basic soldiers. Training booklets were also distributed. The suicide rates in the years 1988–1999 (pre-implementation) were compared to the rates in 2000 and 2001. The total suicide rate over all military personnel in the pre-implementation period was 32.6 per 100,000. The rate for 2000 was 0 and 16.7 for 2001.

Gordana and Milivoje19 reported on a suicide prevention program in the Army of Serbia and Montenegro, influenced by the USAF program of Knox,15 above. The program components included selection (to remove recruits with serious mental problems), education about suicide risk factors, and motivation for military duty. Training was provided to soldiers about maladjustment and substance abuse. Unit and central command physicians, psychologists, and officers were also involved. The program was fully implemented in December 2003. The size of the study population was not reported. The annual suicide rate for the Yugoslav Army for the years 1999 to 2003 was 13 per 100,000, declining in the post-implementation period to 5 per 100,000 in 2004.

In summary, seven studies of suicide prevention for military personnel were identified. All used a conceptual model of risk factor identification, based on review of suicides in the population under study, augmented with factors previously identified by others, followed by educational and organizational changes to reduce those factors or increase education and awareness about them. All were multifaceted programs, and all reported declines in suicides or suicide attempts. However, the reporting of sufficient data to make proper comparison was incomplete, and the quality of the analysis that was reported was generally poor. The largest studies were deployed for the US Navy and Marine Corps and for the US Air Force. The clearly methodologically strongest study was that of Knox et al.15 for the US Air Force, which also appears to have influenced other studies. However, much more data are needed in order to better understand what are the most effective components to include in a multicomponent intervention, and how each component can be both internally optimized and made most synergistic with the other components.

#### Other multifaceted programs (national suicide prevention programs)

Two studies reporting results of multicomponent national suicide prevention programs were identified, one for Australia, and one for England. Both were prospective, cohort designs.

Robinson et al.20 published a commentary on Australia’s National Suicide Prevention Strategy. They divided the interventions in the NSPS into universal (targeting populations), selective (groups with risk factors), and indicated (for groups that have already displayed some suicidal thoughts or behaviors). Most of the interventions were universal interventions aimed at young people or minorities. They noted that neither those with mental illness nor those with previous suicide attempts had been the targets of any of the national initiatives. During the interval of the program’s existence, 1999 to 2004, the suicide rate dropped from 22 to 17 for men, and 5 to 4 for women, both measured per 100,000. As they note, this decline “cannot necessarily be attributed to the NSPS.”

In 2002, England started a national suicide prevention program, the status of which has been documented in a series of yearly updates, the latest of which covers through year 2006.^21^ Their multifaceted program includes mental health (focus on post-hospital discharge and non-compliance with treatment), study of self-harm as a risk for suicide, mental health promotion projects for young men and for those in the prison system. Their program also includes efforts to reduce access to lethal means (removing points for hanging on psychiatric wards, and a phased withdrawal of co-proxamol, a painkiller lethal in overdose), and establishment of systems to conduct suicide audits through Primary Care Trusts. The program set a target of a 20% reduction in suicides during the implementation period. Using age-standardized rates, the rate for 2003–5 was compared the baseline rate for 1995–7. The post-intervention rate was 8.5 deaths per 100,000, which represented at 7.4% decrease from the baseline rate.

In summary, two national suicide prevention programs reported declines in suicide rates coincident with the introduction of those programs. Both published reports provided scant details on methodology.

#### Interventions for veterans

Three reports involving US veterans were identified. This is a heterogeneous set. One was an RCT using psychotherapy for female veterans with borderline personality disorder. One study looked at the association between treatment in a residential program for substance abuse and suicide attempts. One study examined the association between treatment with antidepressant medication and the development of suicidal ideation. (Evidence tables for RCT/CCTs in this section and subsequent sections are shown in Evidence Table 2, which includes the quality assessment ratings; all Military/Veteran Studies are shown in Evidence Table 1)

Koons et al.22 reported a pilot RCT of dialectical behavior therapy for female veterans with borderline personality disorder. Patients with the appropriate diagnosis were recruited through clinics at the Durham VA and other VA clinics in North Carolina. The treatment group received dialectical behavior therapy, a kind of psychotherapy explicitly designed to treat patients with chronic suicidality or self-injurious behaviors. It includes both individual and group therapy, and separate consultation sessions for the therapists, all conducted weekly. The treatment lasted 6 months. The control group received weekly individual therapy. The assessed outcome was intentional self-harm (including suicide attempts) in the preceding 3 months. In the treatment group this decreased from 50% to 10% (at 6 months), and in the control group decreased from 30% to 20%. This decrease was not statistically significant, possibly due to the small sample size (10 patients completed in each group).

Ilgen23 studied US veterans entering substance abuse treatment programs (either residential or outpatient), and compared the suicide attempt rate in the previous 12 months at program entry, during treatment, and in the 12 month follow-up interval. The median treatment duration was 12 months. A total of 3733 patients were followed. In predicting suicide attempts during treatment, residential treatment was associated with a lower rate than outpatient treatment, even when baseline suicidality was controlled for. In predicting suicide attempts after treatment, none of treatment setting (residential vs. outpatient), availability of psychiatric services, and use of psychiatric services was statistically significant, although longer treatment episode was.

Gibbons et al.24 examined the hypothesized association between treatment with antidepressants and the development of suicidal ideation and behavior; earlier studies had led to the FDA’s black box warning for children, adolescents, and young adults for these medications. The authors studied administrative and pharmacy data from the Veteran Health Administration with data on over 226000 patients to identify those patients with new depressive disorders (no history in the prior two years). The outcome variable was suicide attempts treated at VA facilities. Cause of death information was not available for completed suicides. When compared to those depressed patients not receiving an antidepressant, there were reductions in the suicide rate for each class (SSRI monotherapy, non-SSRI monotherapy, and tricyclic monotherapy) studies. When suicide attempt rates were compared within in each class of treatment, the relative risk (in treatment vs. before treatment) was reduced with treatment.

In summary, three studies involving US veterans. One RCT found a trend not reaching statistical significant for the use of dialectical behavior therapy for female veterans with borderline personality disorder. One reported mixed results looking at associations between residential treatment of substance abuse and suicide attempts. One reported reduction in suicide rates associated with treatment with antidepressants. Because of the study designs, it was not possible to infer causality from the reported associations, and the heterogeneity of these studies limits any generalization.

#### Psychosocial interventions post-suicide attempt

Twelve studies were found that described case management or therapeutic interventions initiated after presentations for suicide attempts. These studies are presented here by country, and then chronologically.

##### Psychosocial interventions post-suicide attempt, USA

Welu25 described a program implemented for those making a suicide attempt seen in the emergency room of a hospital in Pittsburgh, Pennsylvania. Patients in the treatment group were seen in a special outreach program staffed by registered nurses, social workers, and community workers. Patients were contacted as soon as possible after release from the hospital to set up home visits. Subsequently mental health treatment designed to meet the needs of that particular patient were made available. Patients were in contact with staff at least biweekly to provide treatment, or to monitor the treatment when it was provided by other services. Patients assigned to the control group were treated in the usual manner in the ER or hospital, and released with written appointments; no attempts were made to provide outreach to those who failed to follow up. Patients were randomized to the treatment or control group. Both groups were contacted for an interview 4 months after the suicide attempt for assessment. The outcome was the number of suicide reattempts in the 4 month follow up period. The treatment group had 4.8% reattempt rate, while the control group had a 15.8% reattempt rate, a statistically significant difference.

##### Psychosocial interventions post-suicide attempt, Canada

Termansen and Bywater26 described a project implemented at Vancouver General Hospital for all patients presenting to that emergency room for a suicide attempt during a three month period in 1972. Patients were allocated to one of four treatment groups on a rotating (nonrandom) basis. The first group was assessed in the ER and followed for three months for the same (lay) mental health worker. The second group was assessed in the ER by a mental health worker, but followed by a crisis center volunteer for three months and then assessed by that volunteer and a mental health worker. The third group received the ER assessment by the mental health worked but with no follow up other than assessment at three months. The fourth group was identified on the basis of ER records, received no other intervention, and was assessed at three months by a mental health worker. The follow up provided to the first two groups was either in-person or by phone on a schedule of decreasing frequency from daily for the first week down to every other week for weeks 9 through 12. They reported the number of suicide attempts in each group: Group 1 had 1/45 (2.2%), Group 2 had 2/33 (6.1%), Group 3 had 7/32 (22%), and Group 4 had 2/18 (11.1%). The lower rate for Group 1 was statistically significant.

Allard et al.27 reported on a follow-up program used in several Montreal hospitals after a suicide attempt. The treatment group received an intensive intervention program consisting of an explicit treatment plan, a schedule of visits for a year, at least one home visit from a social worker, appointment reminders by phone or in writing or home visits for missed appointments, and referral for normal psychiatric treatment at the end of the one-year program. Specific mental health treatment was left to the therapist and could include biologic or psychotherapeutic treatment. The control group received normal care at the hospital. Patients were randomized to the treatment or control group. The outcome assessed was the recurrence of suicide attempts in the two years following the index attempt. They found a recurrence rate of 35% in the treatment group, and 30% in the control group, a statistically insignificant difference. There were three suicide completions in the treatment group and one in the control group.

##### Psychosocial interventions post-suicide attempt, UK

Chowdhury et al.28 described an experimental program at the Regional Poisoning Treatment Centre in Edinburgh, Scotland, for those making repeated suicide attempts, defined as those with a history of one or more prior admissions to that facility within the previous three years. The treatment was a new service staffed by mental health clinicians that offered follow up care in local clinics (either scheduled, or in a walk-in basis), with home visits for all those patients who did not keep scheduled appointments. Arrangements were also made so that patients calling a local suicide hotline would be called by staff, scheduled for an appointment, or seen at home by the service staff. Eligible patients were alternately (not randomly) assigned to either the treatment group or the control group, the latter group receiving the usual treatment of being scheduled with a mental health clinician, but with no attempts to pursue those who failed to keep the appointment. An exception was made for those patients judged to be at high risk of suicide; these patients were automatically assigned to the treatment service, but excluded from the treatment group for comparison in the analysis. The reported outcome was the number of suicide attempts in a six-month follow up period. They found that 24% of the treatment group patients and 23% of the control group patients had one or more suicide attempts, a statistically insignificant difference by the chi-squared test. There were no completed suicides in either group.

Gardner et al.29 reported on a suicide-attempt evaluation program implemented at a hospital in Cambridge, England. All patients admitted for a self-poisoning were randomly assigned for assessment to either a medical team (including a social worker) or a psychiatrist. The medical team members received some (unspecified) instruction in psychiatric evaluation. The purpose of the assessment was to determine whether further inpatient or outpatient psychiatric care was needed. Patients were followed for one year after their attempt. Patient who re-presented at the hospital with subsequent attempts were reentered into the study and re-randomized to an intervention; these patients were thus counted more than once. The outcomes assessed were reattempts or completions. Survival curves for the proportion of admissions without relapse (reattempt) were constructed, and showed a slight but not statistically significant trend for less relapse for those patients assigned to the medical team. A similar result was found when using only first-admission data for each patient. There were no suicides in the medical team group and one suicide in the psychiatrist group.

Gibbons et al.30 reported on a post-suicide social work intervention program at Southampton General Hospital, England. The treatment was a “task-centered casework” approach, in which specific problems in social roles, transitions, or resources were identified, and set out as tasks that the social worker helped the client complete. These services were provided in the patients’ homes. Patient who presented to the hospital Accident and Emergency Department (ER) with deliberate self-poisonings were randomly assigned to either the treatment or the control group of routine treatment (referral back to General Practitioner or to psychiatry). The outcome assessed was the number of recurrences of self-poisoning in the 12 months after the index attempt. The treatment group had 13.5% recurrence rate, while the control group had a 14.5% recurrence rate, a statistically insignificant difference.

Hawton et al.31 reported on a domiciliary (home-based) treatment program for patients admitted to the General Hospital in Oxford, England for deliberate self-poisoning. A special service for such patients was developed using nursing and social work staff, using a problem-oriented crisis intervention approach. In this study the treatment group received these services at home as often as the therapists felt necessary. The control group received the same services provided weekly in clinic. Treatment in both groups lasted up to 3 months. Patients were randomly assigned to either the treatment or control group. The outcome measure was the rate of repetition of suicide attempt. They found the domiciliary group had a repetition rate of 10%, and the out-patient group a rate of 15% in the year following the index overdose. This difference was not statistically significant.

Hawton et al.32 described a program comparing out-patient counseling with referral to General Practitioner care for patients admitted to the General Hospital in Oxford, England for deliberate self-poisoning. The treatment group was given out-patient counseling using a problem-oriented approach by the clinician who conducted the initial assessment. The meaning of the attempt was explored, and alternative coping mechanisms were identified. In the control group patients were referred back to their GPs with recommendations for further care, such as marital therapy. Patients were randomized to the treatment or control group. The outcome assessed was the rate of repeated suicide attempt at one year post-attempt. The treatment group had a 15.4% repeat rate, while the control group had a 7.3% repeat rate; this difference was not statistically significant. There was one completed suicide in the out-patient counseling group; “she had attended OP counseling sessions, but before the end of treatment moved to another area where she was referred to psychiatric care, and where her death occurred.”

Guthrie et al.33 reported on a brief psychological intervention after deliberate self-poisoning implemented at a hospital in Manchester, England. The treatment consisted of four sessions of psychodynamic interpersonal therapy, starting within a week of presentation at the hospital’s emergency department. The therapy was given by a nurse in the patient’s home. The control group was given routine care, which involved assessment in the ER and referral to psychiatry, addiction services, or their general practitioner. Patients were randomized to the treatment or control group. The outcome assessed was further episodes of self-harm within a six-month period. The treatment group had a 9% repeat rate, while the control group had a 28% repeat rate, a statistically significant decrease. There were no completed suicides in either group.

Bennewith et al.34 conducted a cluster randomized controlled trial of a general practice-based intervention in a region of England. For practices include in the treatment group, new episodes of self-harm in patients of those practices were identified. If the episode was the first for that patient during the trial period, the patient’s general practitioner was sent a letter informing them of the incident, along with another letter to forward to the patient inviting the patient to schedule an appointment, and a copy of treatment guidelines for the management of self harm to be placed in the patient’s chart and used during their appointment. The control group received normal referral services. GP practices were randomized to the treatment or control group. The outcome assessed was the recurrence of an episode of deliberate self-harm in the 12 months after the index episode. The treatment group had a recurrence rate of 21.9%, while the control group had a recurrence rate of 19.5%; this difference was not statistically significant. Time to the repeat episode and the number of repeat episodes were also not statistically significantly different.

Clarke et al.35 reported on an intervention for deliberate self-harm, implemented at two Accident & Emergency (ER) departments on the London/Essex border in England. The intervention group received case management services from a nurse practitioner who conducted an initial assessment, constructed a care plan, and was available on a ‘open access’ basis by mobile phone; the NP coordinated access to care but did not provide the services themselves. The intervention group also received the routine care provided to the control group, which comprised triage services and medical and psychiatric treatment as needed. Patients were randomized to the treatment or control group. The outcome assessed was the readmission rate for recurrent self-harm. In the 12 months following the index episode, the treatment group had a 9% readmission rate, while the control group had a 10% readmission rate; this difference was not statistically significant. A statistically significant greater number of patients requiring multiple readmissions were in the treatment group.

##### Psychosocial interventions post-suicide attempt, Australia

Aoun36 described a non-randomized intervention in a region of Western Australia. All patients presenting at one particular hospital or to community clinics after a suicide attempt or who were judged to be at risk of self-harm were offered the intervention. The intervention consisted of a suicide intervention counselor who provided crisis management and coordination of follow-up out to 6 weeks from first contact. Patients could be referred to GPs, other health professionals and agencies. The hospital also enhanced assessment and treatment while in the hospital, and the suicide intervention counselor provided education about risk assessment and treatment resources to health professionals and the community. A 2 year pre-intervention retrospective chart review was conducted to establish the baseline outcomes. Information on the program was collected for 22 months starting in November 1995. The outcome assessed with the number of suicide attempts leading to readmission. Those in the treatment group had a reattempt rate of 3.6%, while those in the standard treatment group had a reattempt rate of 12.6%; this was statistically significant. The pre-intervention rate in the preceding 22 months was 11.1%; this was statistically significant when compared to the treatment group rate. The author did note that during the treatment period the total number of hospital admissions increased; this appears to have been in part driven by a policy to hospitalize for assessment and treatment.

In summary, 12 studies, nearly all randomized or controlled clinical trials, reporting psychosocial interventions post-suicide attempt were identified. Interventions varied, but mostly consisted of additional resources, such as case management to monitor patients, and facilitate access to mental health services. Most studies did not report any statistically significant differences between treatment and control, and in many the proportion of repeat attempts were within a few percent of other. In other studies the average difference was 5%–8% indicating a signal of potential efficacy that possibly could be detected with a larger sample size. The four studies reporting statistically significant results did not differ in any marked way from the nonsignificant studies in terms of patients studied, interventions, or study quality. However, a wide range in suicide attempt rates across studies was noted. The efficacy of these programs does not appear to be robust, and it remains what program characteristics led to the positive results in those four studies, and indeed unclear whether psychosocial interventions aimed at suicide attempters reduce repeated attempts.

#### Postal or telephone follow up post-suicide attempt

Four studies reporting on telephone or postal follow up after suicide attempts were identified. They are presented by country and then by date.

##### Postal or telephone follow up post-suicide attempt, USA

Motto and Bostrom37 described a program in San Francisco for patients admitted to a psychiatric hospital for depression or “suicidal state.” All patients were offered post-discharge therapy. All patients who declined such treatment or discontinued within 30 days were then randomized to either the contact group or the no-contact group. Patients in the contact group received short, personalized letters from the research staff who had conducted their initial interviews expressing concern about the patient, and inviting the patient to respond if they desired. No specific recommendations or treatments were made in the letters. Letters were sent monthly for four months, every two months for eight months, and every three months for four years for a total of 24 contacts over 5 years. Patients in the no-contact group and those who had complied with the initial post-discharge therapy received no letters. The outcome assessed was completed suicides. In five years after the index contact, the treatment (contact) group had a suicide rate of 3.9% compared to the control (no-contact) group at 4.6%. These rates at 15 years were 6.4% for treatment and 5.7% for control. A survival analysis showed statistically significant differences for the first two years, but not later. They concluded that the results were consistent with their study hypothesis: that the period of maximum contact, especially the first year, would have the greater divergence in suicide rate.

##### Postal or telephone follow up post-suicide attempt, UK

Morgan et al.38 reported an intervention to provide patients seen in the Accident and Emergency (ER) department for first episodes of deliberate self-harm with easy access by phone to on-call trainee psychiatrists. This study was conducted in the United Bristol Healthcare Trust catchment area in England. Specifically, those in the treatment group were provided a ‘green card’ which stated that a doctor was available at all times by telephone, and also encouraged patients to seek care by phone or in person at the ER. Those assigned to the treatment group received another copy of the card by mail at their home address three weeks after the index episode. Their GPs were also sent a copy of the card and asked to discuss it with the patients as appropriate. The control group received routine care. Patients were randomized to the treatment or control group. The outcome assessed was the repetition of deliberate self-harm. There were 7 repeats in the treatment group, and 15 repeats in the control group. No completed suicides occurred in either group. Measures of statistical significance were not reported.

Evans et al.39 repeated the study of Morgan et al.38 with the same intervention, modified to allow patients with previous episodes of self-harm, and providing them only phone contact without offers of in-person assessment or hospital admission. Patients were again randomized to the treatment or control group. The rate of repetition of deliberate self-harm in the treatment group was 16.8% compared to 14.4% in the control group. This difference was not statistically significant. There were two completed suicides in the treatment group and one suicide in the control group. They noted that “neither of the suicides from the green card group had made use of the green card at any time to seek help.”

##### Postal or telephone follow up post-suicide attempt, Australia

Carter et al.40 implemented a postcard-based intervention, based on the Motto and Bostrom37 study, for those patients with deliberate self-poisoning presenting at regional toxicology unit in New South Wales, Australia. The intervention consisted of a postcard sent to the patient in a sealed envelope at 1, 2, 3,4, 6, 8, 10, and 12 months post-discharge. The card wished the patient well and invited a response if they were interested. The control treatment was not described. Patients were randomized to the treatment or control group. The outcome assessed was repetition of deliberate self-poisoning. The treatment group had 15.1% with one or more repeat episodes, while the control group had 17.3%; this difference was not statistically significant. The number of repeat episodes in the treatment group was about one half of that in the control group; this was statistically significant.

In summary, four studies of low-intensity post-suicide attempt interventions by phone or mail were identified. The results in the larger studies were either not statistically significant or were of modest efficacy.

#### Community-based Suicide Prevention Centers

Three observational studies about community-based suicide prevention centers were identified.

Walk41 reported on a “Community Care” service implemented in Chichester, England, starting in 1958. The service was described as “with its blurred distinctions between in-patient, day-patient, out-patient and domiciliary treatment, its ready availability and its better contact with the community.” (Unfortunately, no further details about the program were provided.) The suicide rate in five year periods before and after the program was started were compared.Their conclusion was “the introduction of Community Care may have protected some elderly patients from suicide, whereas it has had no clear effect on suicide among younger patients.”

Bagley42 examined data concerning the introduction of the Samaritan Suicide Prevention Schemes in 15 British towns. This program provides a suicide telephone hotline, available day or night. The hotline was staffed by clergy or lay workers who had undergone training designed to provide the workers with the skills to determine if the caller needed referral to clinical services. Each town in which the scheme was implemented was compared to a control town that matched on socioeconomic measures. The outcome assessed was the suicide rate in the same number of years before and after the program started, the actual number determined by the availability of data and ranged from 2 to 4 years. The average rate (per 100,000) for the treatment group towns was 13.03, decreasing to 12.27 after, and the average rate for the control towns was 12.56 before, increasing to 15.05 after. These changes were found to be statistically significant by a variety of measures.

Barraclough et al.43 examined the same data using four different methods of choosing the control towns, including variations on the method of Bagley, matching on the pre-implementation suicide rate, or on the proportion of single-person households. They looked at suicide rates over three year pre- and post-implementation windows. They found no statistically significant difference in the suicide rates.

In summary, three studies of suicide-prevention centers were identified. One reported on an early, and very poorly described community-based program in England. Two examined the effect of the Samaritan Suicide Prevention Scheme in England and reached opposite conclusions. Overall the quality of these studies was low and the results inconclusive.

#### Hospital admission for attempted suicide

One RCT using hospital admission as the intervention for attempted suicide was identified.

Waterhouse and Platt44 conducted their trial at the York District Hospital in England. Junior doctors were trained in the assessment of suicide attempts. Patients who presented to the ER and who were assessed as having no needs for immediate medical or psychiatric treatment were then randomized to either hospital admission or discharge to home. Those admitted to the hospital received no additional counseling or specific treatment. “Hospital admission consisted of little more than a bed, without further referral to other helping agencies.” The median length of stay was 17 hours. The treatment group received the same instructions at discharge as the control group: to contact their general practitioners if the need for help arose. Thus, the treatment group differed from the control group only in the provision of hospital admission. For this pilot study the data were analyzed as if the junior doctor’s initial assessment had been used, while the actual decision was made by the psychiatrist. The outcome assessed was repeated suicide attempts. In the first week post-discharge, two patients in each group had repeated attempts; at 16 weeks 3 patients in the treatment (admission) group had made repeated attempts, compared to 4 patients in the control group. The group sizes were not reported, so percentages can not be computed. No statistical measures were reported.

In summary, a single program studied the effect of brief hospital admission without additional treatment. Insufficient outcomes data were reported to determine its efficacy or statistical significance.

#### Other RCTs

Unutzer et al.45 reported a multi-site trial in the US (including VA clinics in Texas) providing a collaborative care manager to primary care physicians to reduce suicidal ideation in depressed older patients. The depression care manager was a nurse or psychologist assigned to the primary care clinic; they assessed patients, educated patients about options for treating depression, and were in contact with the patients by phone or in-person every 2 weeks during the acute phase of treatment and monthly during the continuation phase continuing to 12 months. Patients in the control group and their primary care providers were informed that the patient met criteria for a depressive disorder; the patients could receive any of the available treatments, including antidepressants, counseling by the PCP, or referral for mental health care. Patients were randomly assigned to the treatment or the control groups. No completed suicides were reported in either group. The intended outcome measure reported for this trial was suicidal ideation, which did show statistically significant decreases at all follow up periods out to 24 months.

Mishara et al.46 described a program implemented in Montreal in 2000–2002 to reduce suicidal behaviors in suicidal or depressed men by providing assistance to family or friends of those men who called a suicidal support center. Family or friends of the suicidal men were randomly assigned to one of four treatment interventions: (1) an information session that provided 2.5 hours of training in a group setting, (2) that information session plus phone follow up one week hence, (3) “rapid referral” for the suicidal man in which the family/friends had two in-person meetings with staff from the suicide center focusing on how to get the suicidal man into treatment with an appropriate agency, (4) telephone support counseling with flexible scheduling of follow up calls. The outcome assessed was suicide attempt. Results were not broken down by treatment group, and there was no control group providing treatment as usual, so the data were analyzed comparing post-intervention to pre-intervention. At study entry 22.9% of the participants reported a suicide attempt in the man in the previous 2 months; at 2 month follow up 10.6% reported an attempt in the previous 2 months, and at 6 month follow up 2.7% reported an attempt in the previous 2 months. Each of these differences was a statistically significant change. Participants also rated these programs as helpful to the men and the participants.

In summary, two other randomized, controlled trials were identified. The first, a high quality RCT, reported a collaborative care program in primary care clinics, and found no suicides in either the treatment or control groups. The second provided an intervention to the family or friends of men at high risk for suicide; the study was methodologically very weak and did not report the effect of treatments in comparison to a control group.

### RESTRICTION OF ACCESS TO LETHAL MEANS

A large number of studies using observational data for restriction of access to lethal means were identified. These are grouped by means, and finally other toxicological agents.

#### Restriction of access to firearms

Twenty studies were identified concerning restriction of access to firearms. These are summarized in Evidence Table 3.

##### Restriction to access to firearms in the US

Loftin et al.47 reported the effect of restrictive licensing of handguns in Washington, D.C., that began in 1976, and which “prohibited the purchase, sale, transfer, and possession of handguns by civilians,” unless the firearm had been previously registered.They compared monthly suicide rates before and after the implementation of the law and found that the mean number of suicides per month declined from 2.6 to 2.0. This was statistically significant, both by a simple sampling model and also by an autoregressive integrated moving average (ARIMA) model commonly used in time-series modeling. To address the problem of secular changes, they studied non-gun-related suicides in the same region, and gun-related suicides in neighboring regions not subject to the law, and found no statistically significant decline in either measure over the same period. This handgun law was found to be unconstitutional by the US Supreme Court in June, 2008.

Ludwig and Cook48 studied whether the introduction of the Brady Handgun Violence Prevention Act in the US, which instituted background checks and waiting periods, was associated with a reduction in suicide rates. Some states already met one or both of the requirements and served as controls; the authors also used regression modeling to control at the state level for alcohol consumption, and percentage of population in metropolitan areas, percentage below the poverty line, percentage African-American, and percentage in each of 7 age groups. They found that suicide rates had begun to fall before the introduction of the Brady Act; the Act was correlated with a reduction in suicides in victims 55 years or older, but only in states that changed both their waiting-period and background-check requirements.

Lott and Whitley49 examined the effect of safe-storage gun laws in the US (which varied by state), and suicides in adolescents, including those in the age range of 15–19 years. Using data from the years 1979 to 1996, during which time 15 states adopted safe-storage laws (the year of enactment ranged from 1989 to 1996), they used weighted tobit regression models predicting the per capita suicide rate from a variety of fixed effect and control variables. The results showed a 5% decrease in gun suicides attributable to the safe-storage law; this was not statistically significant. A second set of more sophisticated regression models found: “… a couple of coefficients that indicated that gun suicides declined after the passage of the safe-storage law. However, in these cases, the evidence clearly rejects the hypothesis that the total number of suicides, committed by all methods, would be reduced.”(p677). They did not provide the details supporting those results.

A similar study by Rosengart et al.50 examined various kinds of handgun restriction laws in the US, using data from 1979 to 1998, and found that no law was statistically significantly associated with a change in the firearm suicide rate (in any age group). Webster et al.51 examined related data from 1976 to 2001, for the age group of 18–20 years of the effects of minimum purchase age or child access prevention laws. They, found results that were either statistically insignificant or were of questionable causal believability for that age group.

##### Restriction of access to firearms in Canada

In Canada, a firearms control law was enforced starting in 1978 that required licensing, restricted certain sales, and increased criminal penalties for crimes involving firearms.The effects of this law have been examined in a number of studies, reported here chronologically.

Rich et al.52 examined the law’s effect in Toronto and Ontario. Mean rates in the five year periods before and after the law were compared; the data for the year 1978 were withheld because of the transition during the year. There was a small but not statistically significant decrease in the suicide rate for Toronto or for Ontario. They did find a statistically significant decrease in the fraction of suicides by shooting for men in Toronto, and a statistically significant increase in the fraction of men committing suicide by jumping. They considered this evidence of method substitution.

Carrington and Moyer53 repeated the analysis of the data for Ontario studied by Rich et al.52 using a slightly different data source, extended to include 1965–1977 and 1979–1989, and using age-standardized rates in a regression analysis. They found statistically significant increases in the firearm, non-firearm, and total suicide rates in the pre-legislation period, and decreases in those three rates (not significant for firearm suicide) in the post-legislation period. They considered their results as suggesting no method substitution.

Lester and Leenaars54,55 looked at the law’s effect for all of Canada for the 8 years prior (1969 to 1976) and eight years after (1978 to 1985). Examination of the raw statistics showed that the rate of suicide by firearm and fraction of suicide by firearm had a statistically significant decrease, but that both the overall suicide rate and the suicide rate by other means increased. A post-hoc linear regression analysis showed that before the law, the rates for suicide by firearm and by other methods, along with the fraction of suicides by firearm were all increasing, while after the law was enforced, these quantities were all decreasing (although the suicide rate by other methods was not statistically significant). They concluded that there was not evidence for method substitution.

Leenaars and Lester56 examined the same data separately for men and women. For men, the firearms suicide rate and the rate for other methods both increased in the post-legislation period, while the fraction of men using firearms for suicide decreased. They considered this is as evidence of switching in men. For women, the rates were stable or declined, and there was no evidence for switching.

Lester57 reanalyzed the Canadian data using two alternative measure of firearms availability: accidental death rate from firearms, and average of fraction of suicides and homicides committed by firearm. These data were available statistically significantly correlated with the firearm suicide rate (positively) and both the total suicide rate and the suicide rate by other methods (negatively). Lester also found a negative time trend for the firearm suicide rate, and a positive time trend for the suicide rate by other methods. Lester concluded that these data were consistent with method substitution.

Leenaars and Lester58 reexamined the Canadian data to determine the effect of the legislation on suicide rates by age group. The post-legislation mean handgun suicide rates declined for ages 35–44, 45–54, and 55–64 (all statistically significantly), and increased for ages 15–24, 25–34, 65–74, and 75+ (the increases for 25–34 and 65–74 were not statistically significant).They concluded that there was little evidence for the effectiveness of the act in reducing suicide for those 65 and up.

Leenaars et al.59, looked at the same data using regression modeling. The firearm suicide rate showed an increasing trend before the legislation, no step-effect at the time of the legislation, and a negative slope for the interaction term, indicating a declining trend after the legislation. The same pattern was seen in the data for men only, but for women the pre-legislation trend was not significant and the post-legislation decline was statistically significant but small in magnitude. The results also suggested a displacement effect for men, but not for women. The authors also conducted a multivariate regression including a variety of social indicators, such as income, and birth, marriage, and divorce rates as predictor variables. This showed a statistically significant decrease in firearm suicide rates for both men and women, and evidence for switching in men.

Bridges60 used a similar approach to examine the effect of a different Canadian law passed in 1991 that mandated additional pre-purchase screening and a 28-day waiting period over 7 years periods before and after the introduction of the law. The mean rate for firearm suicide and the fraction of suicide by firearm decreased, while the total suicide rate increased.Trends were checked by using separate linear regressions in the pre- and post-legislation periods. The total suicide rate, the firearms suicide rate, the rate for other methods, and the fraction of suicides by firearm all had negative slopes in the pre-legislation period; in the post-legislation period there were negative (but small) slopes for the firearms suicide rate and the fraction of suicide by firearms. There was no evidence for switching.

Cheung and Dewa61 examined the effect of the same Canadian 1991 law on the suicide rate in adolescents ages 15–19. Using a time-series model over the years 1979–1999, they found a decrease in the firearms suicide rate after 1991, but a corresponding increase in the rate of hanging, consistent with method switching.

##### Restriction to access to firearms in Australia/New Zealand

Snowdon and Harris62 looked at the firearm suicide rate in Australia’s five largest states, one of which (South Australia) enacted a stringent firearm examination and licensing law in 1980. The suicide rates were examined over the years 1968 to 1989. The rate in South Australia was statistically significantly lower when compared to the four other states, and when compared directly with the state of Victoria, the most similar state on demographic measures. The decrease in South Australia was accompanied by an increase in suicide by other means. They were unable to reach firm conclusions about method substitution.

Chapman et al.63 studied whether Australia’s firearms restrictions, which were enacted in 1996 and included prohibitions on private ownership of semi-automatic and pump-action rifles and shotguns, and also a buy-back program of existing firearms, were associated with a reduction in suicide rates. The data were analyzed using a negative binomial model. The authors reported that the firearm suicide rate, which was already decreasing at 3% per year, further dropped to 7.4% per year after the law change. The total suicide rate changed from a 2.3% increase per year to a 4.1% decrease, although at the time of the law change, the total rate did transiently increase in absolute numbers.

Cantor and Slater64 examined the effect of firearm control legislation in the state of Queensland requiring a 28 day waiting period and a safety test which came into effect in 1992 on the suicide rate in metropolitan, provincial, and rural areas in that state. The mean annual suicide rate per 100,000 in the two years before the change was compared to the rate in the two years following the change. There were statistically significant decreases in the firearms suicide rate in the metropolitan (3.6 to 2.3) and provincial (5.2 to 3.1) but not in the rural areas (7.2 to 8.2, non-significant). A subgroup analysis showed that the significant decreases were in men age 15–29 in the metropolitan and provincial areas. There were statistically significant increases by men in metropolitan and provincial areas in the use drug overdose and hanging, although the total rate for men decreased slightly.

Ozanne-Smith et al. 65studied the effect of firearm regulation in Australia, introduced first in the state of Victoria, and then several years later in the rest of Australia. The legislation banned certain classes of firearms, required registration and a safety class, and included a 1 year longarms buyback scheme. They used a Poisson regression model with data over three periods: 1979–86 (no legislation), 1988–1995 (legislation introduced in Victoria), and 1997–2000 (similar legislation introduced in rest of Australia). The suicide rates in Victoria declined in each successive period at a statistically significant rate (a 72% decline in the average annual frequency from the first to the third period). They did not report on data directly relevant to the problems of displacement or method substitution.

Beautrais et al.66 reported on reduction of suicide rates in New Zealand associated with restrictive firearms legislation, enacted in 1992, and which mandated police assessment, testing, and licensing of gun owners, along with strict requirements for gun security and storage. Their analysis used a variety of regression models, including Poisson regression, a time-series forecasting model, a polynomial model, and an auto-regressive model, over three intervals: before the implementation, the four-year period of implementation (1993–96), and after the implementation period. They reported a decline in the suicide rate for youth (15–24y), adult (25+y), and combined populations over time; this trend was most marked for youth suicide. A similar pattern was seen for firearm suicide as a percentage of total suicides. Use of various models showed no evidence for a decline in the overall rate of suicide.

In summary, a large number of studies concerning restricting access to firearms were identified. A number of the studies reported variations on analyses of the same or very similar data sets. All compared the suicide rates before and after the implementation of laws restricting access to firearms. Methodological issues common to the analysis of observational data were present, especially addressing statistical fluctuations by using longer windows for the pre- or post-intervention periods, while trying to minimize the effect of other, unmeasured, socioeconomic trends, such as changes in the divorce or unemployment rate. The results as reported are mixed, but suggest some protective effect at least in some groups as determined by age and gender. The question of possible shifts to other methods leading to no net reduction in suicide (method substitution) remains unresolved.

##### Restriction of access to acetaminophen (UK: paracetamol, US Brand: Tylenol, others)

The UK enacted legislation in September 1998 that limited the package size of paracetamol and salicylates (including aspirin). Paracetamol is commonly used in suicide by overdose and if untreated can cause fatal liver failure. The effect of this legislation has been reported in a number of studies, presented here chronologically.

Prince et al.67 reported on the number of patients referred to a tertiary care liver unit at a single hospital, and the number of national liver transplantation requests from September 1995 to August 1999. Monthly rates for both declined after the legislation, in spite of a preexisting increasing trend in national transplant referrals.

Turvill et al.68 reported on the number of paracetamol overdoses at one London hospital from September 1995 to August 1999. The number of overdoses declined by 21% (with a 64% decline in severe overdoses, as determined by existing guidelines) after the legislation. There was no change in the rate of benzodiazepine overdoses, which served as a control measure.

Robinson et al.69 measured the several parameters before the legislation (January through June 1998) and after (same months, 1999) in patients at a hospital in Belfast. They found statistically significant decreases in the estimated quantity of paracetamol ingested, the serum paracetamol concentration, the percentage of patients admitted to the hospital, the percentage of patients given antidote, a measure of liver function (INR) and concentrations of liver enzymes.

Steen et al.70 examined the effect of the legislation on paracetamol-related deaths in Scotland. They compared all paracetamol-related deaths in the years 1996–1997 and the years 1999–2000. The rate for the two years preceding the year of implementation was 1.93 per 100,000; the rate for the latter two years was 1.78 per 100,000. This change was not significant by the chi-square test. Informally, they observed a declining trend in the paracetamol-only deaths in males before the legislation, which reversed in the year 2000. They also noted that Scotland has a markedly higher suicide rate than England or Wales.

Hughes et al.71 counted the number of admissions to a Birmingham, UK hospital or a related hospital’s liver unit as the result of paracetamol poisonings for three years before and three years after 1998. Hospital admissions showed a 31% reduction, and liver unit admissions showed a 50% reduction. No statistical analysis was conducted.

Hawton et al.72 and Hawton73 compared the suicide deaths in the two years before the change with the deaths in the year after the change. There were statistically significant reductions in deaths for both classes of compounds considered individually, but not when taken with other drugs or taken together. They also found that the number of admissions to hospital liver units and the number of liver transplantations declined over the same intervals. The number of non-fatal self-poisonings with paracematol or salicylates declined in absolute numbers, comparing the previous year to the subsequent year, but there was no decline the proportion of total cases of self-poisoning. They concluded that “legislation restricting pack sizes of paracetamol and salicylates in the United Kingdom has had substantial beneficial effects on mortality and morbidity associated with self-poisoning using these drugs.”

Hawton et al.74 repeated the above analysis, adding another post-legislation year, and also included trend modeling with data from 1993 to 2002 to test for step change at the time of the legislation. They found a 29% decrease in paracetamol-related deaths, and 46% decrease in salicyclate-related deaths. They also evidence for a downward step change for both paracetamol and salicyclate overdoses at the time of the legislation. Liver unit admissions, liver transplants, and nonfatal paracetamol and aspirin overdoses decreased after the legislation.

Morgan et al.75 analyzed UK national data for the package restriction using chi-square (and later analyzed the same data using segmented linear regression: Morgan et al.76). To control for secular trends, they compared the paracetamol deaths to those from paracetamol in combination with other compounds, aspirin (which was also limited by the same legislation), antidepressants, and non-drug poisoning suicides. There were declines (negative slopes) in age-standardized mortality rates for all the groups studied. There was a downward step change in those rates for paracetamol poisoning, with a similar step change for aspirin and antidepressants, but not for paracetamol compounds or non-drug poisoning suicides. Thus, while the paracetamol deaths declined, other suicide deaths also declined over the same period. They conclude that there is “little evidence” to associate the reduction in paracetamol-related suicides with the package size reductions.

Similar restrictions in Ireland were introduced starting in October 1997. An abstract by Donohoe and Tracey77 reported no statistically significant difference in the number of overdose cases reported to the National Poisons Information Centre in Dublin in 1998, compared to 1997. There was a slight but not statistically significant decline in severe overdoses.

For Australia, Balit et al.78 reported on the effect of a recall of paracetamol-containing products during two periods in 2000 in response to threatened insertion of poisons into those products. The outcome measures were the number of calls to a poison information center and the number of admissions to a toxicology inpatient service, both in New South Wales. These measures during the recall periods were compared with corresponding measures in the same months of the three preceding years (1997–1999). At one site, there was no statistically significant change in the percentage of calls for paracetamol or aspirin, but an increase for ibuprofen; at the other site, there was no statistically significant change in the presentations for paracetamol or ibuprofen, but an increase for aspirin. They concluded that there was no reduction in deliberate self-poisonings during a period of restricted availability.

In summary, a number of studies of the effect of UK restrictions on paracetamol showed declines in suicides coincident with those restrictions. However, there is some evidence from time-series modeling that this was part of a longer downward trend in suicide. Many of the studies had very short post-intervention periods. A small of number of studies in other countries reported equivocal results. Unlike the area of restriction of access to firearms, there was little analysis of method substitution.

#### Restriction of access to respiratory toxins

Kreitman79 studied deaths due to asphyxiation by “domestic gas” in the UK (England, Wales, Scotland) in relationship to changes in the production of such gas from coal to natural gas that significantly lowered the carbon monoxide content over approximately a decade starting in the late 1950s. Kreitman reported that the reduction in carbon monoxide content was paralleled by a drop in carbon monoxide poisoning deaths during that same interval; this was found in both sexes and all age groups. The decline was significant enough to overcome an increase in the other rates of suicide for both young men and women to produce a net overall decline.

Kendell80 reported data on the effect in Scotland of the UK regulation requiring all cars sold after December 31, 1992 to have catalytic converters, thereby decreasing the carbon monoxide content of the exhaust gas. For men, the fraction of all suicides attributed to poisoning by gases other than domestic gas showed a statistically significant decline (chi-square for trend), with a smaller but also statistically significant decline for women. A data over a somewhat shorter interval in England and Wales showed the same pattern.

Amos et al.81 studied deaths due to carbon monoxide poisoning by car exhaust in England and Wales for the years before (1987–1992) and after (1993–1998) European legislation requiring that all new car have catalytic converters. For all age groups and both sexes there was a decline in deaths from car exhaust, and in the percentage of all suicides that were due to car exhaust. These comparisons were made using the raw statistics, not age/population adjusted numbers. They also performed a hierarchical multiple linear regression that included an interaction term that was the product of the two study periods; however, they reported only the statistical tests on the regression analysis, not the coefficients. They noted that the decline in car exhaust asphyxiations had started, at least in some groups, prior to the implementation of the law.

Routley82 conducted a similar study in Australia, where 1986 regulations added catalytic converters to new cars. Using data from 1971 to 1995, they found that motor vehicle exhaust gas suicide rates increased generally increased over time, even after the regulation. Numbers of patients hospitalized for motor vehicle exhaust gas suicide attempts also increased during the interval. A sample of 100 cases of exhaust gas suicide in the state of Victoria were reviewed. The fraction of vehicles used in these suicides manufactured after 1986 was not significantly different from the fraction for the Victorian motor fleet at large. They concluded that catalytic converters were not associated with a decline in motor vehicle exhaust suicide number, rate, or proportion.

In summary, four studies were found concerning restricting access to respiratory agents. One study found that changing the source of domestic gas in the UK resulted in a decrease in carbon monoxide poisonings. The effect of catalytic converters on car exhaust asphyxiation reported in three studies was mixed.

#### Access to/effect of pharmacologic agents

Oliver and Hetzel83 reported on the relationship between changes in the availability of sedative drugs due to subsidization of health care in Australia in 1960, which increased the availability and a subsequent reduction in 1967 of the amounts provided in each prescription, and the effect on the national suicide rate over the same time period. They found an increase in the incidence of barbiturate deaths in adults during the time of increased availability, and a subsequent decrease with the limitation on sedative amounts.

Whitlock84 conducted a similar study in Brisbane, Australia, for the years 1962 to 1973, and found a similar result: that barbiturate suicide deaths tracked their increase and then decrease in availability. This effect was more prominent in women, for whom barbiturate overdose was more common. There was already an increasing trend in suicide rates before the increase associated with the availability of barbiturates. Whitlock also addressed the changing use of other medications, such as benzodiazepines and antidepressants, which might have substituted for barbiturates, either therapeutically or as methods of self-poisoning, but the fact that the changes in use extended over multi-year periods, and the lack of a single intervention greatly complicates the analysis of this observational data, and the detection of method substitution and secular trends. Whitlock did note that there had been no deaths from carbon monoxide poisoning in those aged 65 and older after 1967, when domestic gas was switched to a nontoxic source.

In summary, two studies in Australia on the effect of access to sedative drugs lethal in overdose showed a decline in the suicide rate that tracked restrictions on their availability.

#### Bridge barriers

One study on the effect of bridge barriers in reducing suicide by jumping was identified.

Beautrais85 reported on the effect of removing existing screens from a bridge in an “Australasian metropolitan area.” The location was described in a disguised fashion so as to avoid attracting further attention to it. Existing screens were removed by the action of the city council in 1995 because they were felt to actually impede access to rescuing suicide attempters and for aesthetic reasons. Suicide rates by jumping at that bridge and other bridges were compared in three-year periods before and after the barrier removal. The rate (per 100,000) at the bridge before the barriers were removed was 0.29; this increased to 1.29 after the removal. The number of suicides at the other bridges declined after the barrier removal, and the citywide total before and after remained constant. Beautrais presented additional data on the subject’s mental health diagnosis (mostly, schizophrenia) suggesting that the act of barrier removal increased the suicide rate for mental patients because of its location near the regions largest inpatient psychiatric facility, and that the removal did not merely shift suicides from other bridges.

In summary, a single observational study reported an increase in suicide by jumping after protective screens were removed from a bridge; there was some evidence that the removal led to an actual increase in suicide, not merely displacement from other bridges.

#### Restriction on Media Reporting of Suicides

One controlled study reported on media restriction of reporting of suicides.

Motto86 examined the suicide rate in Detroit during a 268-day period in 1967–8 when a newspaper strike lead to the complete cessation of publication. The suicide rate of the blackout period was compared to the average rate during the same days in the previous four years. The rate for men was the same (16.7 per 100,000), while the rate for women dropped from 7.6 to 3.0; the decline was statistically significant. An overall declining trend starting before the blackout period was noted.

In summary, a single observational study on media restriction during an extended newspaper strike showed a decline in suicides for women, and no change for men. There may have been an preexisting declining trend in suicide starting before the strike.

## KEY QUESTION #3: What evidence is still needed to establish various strategies as the most promising (framed as research questions to guide and focus continued research to expand knowledge regarding the effectiveness of suicide prevention approaches)?

Multifaceted interventions are supported by consistent evidence, although of very mixed quality. Even if such programs are later determined to be robustly successful, the question of which components in those programs are causally related to the reduction in suicides has not been addressed. This sets as a research issue determining which components work best in which combinations for which populations. The issue of whether some sets of components may have facilitative or synergistic effects has not been addressed.

Psychosocial intervention for suicide attempters have considerable face validity as they address a group with manifest evidence of suicide risk, but there is no consistent evidence in their support in spite of a moderate number of randomized controlled trials that been conducted. This is an area of obvious and considerable interest to the VA, which is now using similar approaches in its clinical programs to identify and track those at high risk with suicide risk flags, screening tools, and suicide prevention coordinators. An additional factor that seems relevant but rarely directly studied is the effect of forming a consistent relationship with a single provider, a therapeutic alliance, and its role in providing a protective degree of social connection, and reducing the harmful consequences of social isolation.

Further randomized controlled trials and high-quality observational studies are definitely needed. Without waiting for such to be completed, and independent of which program components the VA decides to pursue, there are two supporting initiatives that could be implemented in parallel. The first concerns standardizing vocabulary, and the second concerns electronic medical records.

First, all suicide prevention programs are dependent on the accuracy with which assessments of suicidality are conducted. The term “suicide attempt” covers a very broad array of self-injurious behaviors, from intentionally planned, high lethality events that were interrupted by mere happenstance, through low lethality acts marked by a small risk of physical harm, impulsivity, and a high likelihood of discovery by others. Others have noted the importance of establishing and using a consistent nomenclature in this area.

A very important reason for accurately describing the severity of suicide attempts is that an attempt is widely recognized as a significant risk factor for completions. Although most completed suicides are first attempts2 and attempters vary in important ways from completers,3 it is known that survivors of highly lethal attempts have similar clinical and psychosocial profiles to antemorten profiles of suicide completers. This suggests that subcategorization of attempt by lethality (or perhaps other factors) may be clinically useful.

Second, because the VA uses a single, integrated computerized medical record system for all of its clinical activities, any improvements in vocabulary along with new screening and tracking tools would allow for data gathering as part of routine practice – especially for establishing patterns and risk factors for suicide attempts – in advance of formally conducted observational studies or controlled trials.