# REFERENCES

1 Mann JJ, Apter A, Bertolote J, Beautrais A, Currier D, Haas A, et al. Suicide prevention strategies: a systematic review. JAMA. 2005;294:2064-74. [pmid: 16249421].
2 Mann JJ. A current perspective of suicide and attempted suicide. Ann Intern Med. 2002;136:302-11. [pmid: 11848728].
3 Paris J. Predicting and preventing suicide: do we know enough to do either?. Harv Rev Psychiatry. 2006;14:233-40. [pmid: 16990168].
4 Hankin CS, Spiro A 3rd, Miller DR, Kazis L. Mental disorders and mental health treatment among U.S. Department of Veterans Affairs outpatients: the Veterans Health Study. Am J Psychiatry. 1999;156:1924-30. [pmid: 10588406].
5 Zivin K, Kim HM, McCarthy JF, Austin KL, Hoggatt KJ, Walters H, et al. Suicide mortality among individuals receiving treatment for depression in the Veterans Affairs health system: associations with patient and treatment setting characteristics. Am J Public Health. 2007;97(12):2193-8. Serious Mental Illness Treatment Research and Evaluation Center (SMITREC), Health Services Research and Development (HSR&D) Center of Excellence, Department of Veterans Affairs, Ann Arbor, Mich, USA. kzivin@umich.edu. [pmid: 17971541].
6 Milliken CS, Auchterlonie JL, Hoge CW. Longitudinal assessment of mental health problems among active and reserve component soldiers returning from the Iraq war. JAMA. 2007;298:2141-8. [pmid: 18000197].
7 Gaynes BN, West SL, Ford CA, Frame P, Klein J, Lohr KN. Screening for suicide risk in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140:822-35. [pmid: 15148072].
8 Pirkis J, Blood RW, Beautrais A, Burgess P, Skehans J. Media guidelines on the reporting of suicide. Crisis. 2006;27:82-7. [pmid: 16913330].
9 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271-8. [pmid: 1834807].
10 Shea BJ, Grimshaw JM, Wells GA, Boers M, Andersson N, Hamel C, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
11 Verhagen AP, de Vet HC, de Bie RA, Kessels AG, Boers M, Bouter LM, et al. The Del-phi list: a criteria list for quality assessment of randomized clinical trials for conducting systematic reviews developed by Delphi consensus. J Clin Epidemiol. 1998;51:1235-41. [pmid: 10086815].
12 Atkins D, Best D, Briss PA, Eccles M, Falck-Ytter Y, Flottorp S, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328:1490. [pmid: 15205295].
13 James LC, Kowalski TJ. Suicide prevention in an army infantry division: a multi-disciplinary program. Mil Med. 1996;161:97-101. [pmid: 8857222].
14 McDaniel WW, Rock M, Grigg JR. Suicide prevention at a United States Navy training command. Mil Med. 1990;155:173-5. [pmid: 2110340].
15 Knox KL, Litts DA, Talcott GW, Feig JC, Caine ED. Risk of suicide and related adverse outcomes after exposure to a suicide prevention programme in the US Air Force: cohort study. BMJ. 2003;327:1376. [pmid: 14670880].
16 Jones DE, Kenedy KR, Hawkes C, Hourani LA, Long MA, Robbins D. Suicide prevention in Navy and Marine Corps: applying the public health model. Navy Med. 2001;92:31-6.
17 Kennedy CH, Cook JH, Poole DR, Brunson CL, Jones DE. Review of the first year of an overseas military gambling treatment program. Mil Med. 2005;170(8):683-7. Substance Abuse Rehabilitation Program, United States Naval Hospital, Okinawa, Japan. [pmid: 16173209].
18 Rozanov VA, Mokhovikov AN, Stiliha R. Successful model of suicide prevention in the Ukraine military environment. Crisis. 2002;23:171-7. [pmid: 12617482].
19 Dedic G, Panic M. Suicide prevention program in the Army of Serbia and Montenegro. Mil Med. 2007;172(5):551-5. Department for Mental Health, Military Medical Academy, 11000 Belgrade, Crno- travska 17, Serbia. [pmid: 17521110].
20 Robinson J, McGorry P, Harris MG, Pirkis J, Burgess P, Hickie I, et al. Australia’s National Suicide Prevention Strategy: the next chapter. Aust Health Rev. 2006;30(3):271-6. ORYGEN Research Centre, University of Melbourne, 35 Poplar Road, Parkville, Mel-bourne, VIC 3052, Australia. jo.robinson@mh.org.au. [pmid: 16879085].
21 National Suicide Prevention Strategy for England. National Institute for Mental Health in England, Care Services Improvement Partnership.
22 Koons CR, Robins CJ, Tweed JL, Lynch TR. Efficacy of dialectical behavior therapy in women veterans with borderline personality disorder. Behavior Therapy. 2001;32:371-90.
23 Ilgen MA, Jain A, Lucas E, Moos RH. Substance use-disorder treatment and a decline in attempted suicide during and after treatment. J Stud Alcohol Drugs. 2007;68(4):503-9. Center for Health Care Evaluation, Department of Veterans Affairs Palo Alto Health Care System, 795 Willow Road (MPD 152), Menlo Park, California 94025, USA. Mark.Ilgen@va.gov. [pmid: 17568953].
24 Gibbons RD, Brown CH, Hur K, Marcus SM, Bhaumik DK, Mann JJ. Relationship between antidepressants and suicide attempts: an analysis of the Veterans Health Administration data sets. Am J Psychiatry. 2007;164(7):1044-9. Center for Health Statistics, University of Illinois at Chicago, Chicago, IL 60614, USA. rdgib@uic.edu. [pmid: 17606656].
25 Welu TC. A follow-up program for suicide attempters: evaluation of effectiveness. Suicide Life Threat Behav. 1977;7:17-20. [pmid: 206990].
26 Ternansen PE, Bywater C. S.A.F.E.R.: A follow-up service for attempted suicide in Van-cover. Canadian Psychiatric Association Journal. 1975;20:29-34. [pmid: 164270].
27 Allard R, Marshall M, Plante MC. Intensive follow-up does not decrease the risk of repeat suicide attempts. Suicide Life Threat Behav. 1992;22:303-14. [pmid: 1440744].
28 Chowdury N, Hicks RC, Kreitman N. Evaluation of an after-care service for parasuicide (attempted suicide) patients. Social Psychiatry. 1973;8:67-81.
29 Gardner R, Hanka R, O’Brien VC, Page AJ, Rees R. Psychological and social evaluation in cases of deliberate self-poisoning admitted to a general hospital. Br Med J. 1977;2:1567-70. [pmid: 589349].
30 Gibbons JS, Butler J, Urwin P, Gibbons JL. Evaluation of a social work service for self-poisoning patients. Br J Psychiatry. 1978;133:111-8. [pmid: 678733].
31 Hawton K, Bancroft J, Catalan J, Kingston B, Stedeford A, Welch N. Domiciliary and out-patient treatment of self-poisoning patients by medical and non-medical staff. Psy-chol Med. 1981;11:169-77.
32 Hawton K, McKeown S, Day A, Martin P, O’Connor M, Yule J. Evaluation of out-patient counselling compared with general practitioner care following overdoses. Psychol Med. 1987;17:751-61. [pmid: 2819914].
33 Guthrie E, Kapur N, Mackway-Jones K, Chew-Graham C, Moorey J, Mendel E, et al. Randomised controlled trial of brief psychological intervention after deliberate self poisoning. BMJ. 2001;323:135-8. [pmid: 11463679].
34 Bennewith O, Stocks N, Gunnell D, Peters TJ, Evans MO, Sharp DJ. General practice based intervention to prevent repeat episodes of deliberate self harm: cluster randomised controlled trial. BMJ. 2002;324:1254-7. [pmid: 12028981].
35 Clarke T, Baker P, Watts CJ. Self-harm in adults: a randomised controlled trial of nurseled management versus routine care only. Journal of Mental Health. 2002;11:167-176.
36 Aoun S. Deliberate self-harm in rural Western Australia: results of an intervention study. Aust N Z J Ment Health Nurs. 1999;8:65-73. [pmid: 10661074].
37 Motto JA, Bostrom AG. A randomized controlled trial of postcrisis suicide prevention. Psychiatr Serv. 2001;52:828-33. [pmid: 11376235].
38 Morgan HG, Jones EM, Owen JH. Secondary prevention of non-fatal deliberate self-harm. The green card study. Br J Psychiatry. 1993;163:111-2. [pmid: 8353677].
39 Evans MO, Morgan HG, Hayward A, Gunnell DJ. Crisis telephone consultation for deliberate self-harm patients: effects on repetition. Br J Psychiatry. 1999;175:23-7. [pmid: 10621764].
40 Carter GL, Clover K, Whyte IM, Dawson AH, D’Este C. Postcards from the EDge project: randomised controlled trial of an intervention using postcards to reduce repetition of hospital treated deliberate self poisoning. BMJ. 2005;331:805. [pmid: 16183654].
41 Walk D. Suicide and community care. Br J Psychiatry. 1967;113:1381-91. [pmid: 6078493].
42 Bagley C. The evaluation of a suicide prevention scheme by an ecological method. Soc Sci Med. 1968;2:1-14. [pmid: 5688226].
43 Barraclough B, Jennings C, Moss JR. Suicide prevention by the Samaritans. Lancet. 1977;24:868-870.
44 Waterhouse J, Platt S. General hospital admission in the management of parasuicide. A randomised controlled trial. Br J Psychiatry. 1990;156:236-42. [pmid: 2180527].
45 Unutzer J, Tang L, Oishi S, Katon W, Williams JW Jr, Hunkeler E, et al. Reducing suicidal ideation in depressed older primary care patients. J Am Geriatr Soc. 2006;54(10):1550-6. Department of Psychiatry, School of Medicine, University of Washington, Seattle, Washington 98195, USA. unutzer@u.washington.edu. [pmid: 17038073].
46 Mishara BL, Houle J, Lavoie B. Comparison of the effects of four suicide prevention programs for family and friends of high-risk suicidal men who do not seek help themselves. Suicide Life Threat Behav. 2005;35(3):329-42. Centre for Research and Intervention on Suicide and Euthanasia, Montreal, Canada. mishara.brian@uqam.ca. [pmid: 16156493].
47 Loftin C, McDowall D, Wiersema B, Cottey TJ. Effects of restrictive licensing of handguns on homicide and suicide in the District of Columbia. N Engl J Med. 1991;325:1615-20. [pmid: 1669841].
48 Ludwig J, Cook PJ. Homicide and suicide rates associated with implementation of the Brady Handgun Violence Prevention Act. JAMA. 2000;284:585-91. [pmid: 10918704].
49 Lott JR Jr, Whitley JE. Safe storage gun laws: accidental deaths, suicides, and crime. J Law Econ. 2001;44:6596-6689.
50 Rosengart M, Cummings P, Nathens A, Heagerty P, Maier R, Rivara F. An evaluation of state firearm regulations and homicide and suicide death rates. Inj Prev. 2005;1:77-83. [pmid: 15805435].
51 Webster DW, Vernick JS, Zeoli AM, Manganello JA. Association between youth-focused firearm laws and youth suicides. JAMA. 2004;292:594-601. [pmid: 15292085].
52 Rich CL, Young JG, Fowler RC, Wagner J, Black NA. Guns and suicide: possible effects of some specific legislation. Am J Psychiatry. 1990;147:342-6. [pmid: 2309953].
53 Carrington PJ, Moyer S. Gun control and suicide in Ontario. Am J Psychiatry. 1994;151:606-8. [pmid: 8147463].
54 Lester D, Leenaars A. Suicide rates in Canada before and after tightening firearm control laws. Psychol Rep. 1993;72:787-90. [pmid: 8332684].
55 Lester D, Leenaars A. Gun control and rates of firearm violence in Canada and the United States: a comment. Canadian Journal of Criminology. 1994;36:463-464.
56 Leenaars AA, Lester D. Gender and the impact of gun control on suicide and homicide. Archives of Suicide Research. 1996;2:223-34.
57 Lester D. Gun availability and the use of guns for suicide and homicide in Canada. Can J Public Health. 2000;91:186-7. [pmid: 10927845].
58 Leenaars A, Lester D. The impact of gun control on suicide and homicide across the life span. Canadian Journal of Behavioral Science. 1997;29:1-6.
59 Leenaars AA, Moksony F, Lester D, Wenckstern S. The impact of gun control (Bill C-51) on suicide in Canada. Death Stud. 2003;27:103-24. [pmid: 12675070].
60 Bridges FS. Gun control law (Bill C-17), suicide, and homicide in Canada. Psychol Rep. 2004;94:819-26. [pmid: 15217033].
61 Cheung AH, Dewa CS. Current trends in youth suicide and firearms regulations. Can J Public Health. 2005;96:131-5. [pmid: 15850034].
62 Snowdon J, Harris L. Firearms suicides in Australia. Med J Aust. 1992;156:79-83. [pmid: 1736081].
63 Chapman S, Alpers P, Agho K, Jones M. Australia’s 1996 gun law reforms: faster falls in firearm deaths, firearm suicides, and a decade without mass shootings. Inj Prev. 2006;12(6):365-72. School of Public Health, University of Sydney, Sydney, New South Wales, Australia. sc@med.usyd.edu.au. [pmid: 17170183].
64 Cantor CH, Slater PJ. The impact of firearm control legislation on suicide in Queensland: preliminary findings. Med J Aust. 1995;162:583-5. [pmid: 7791644].
65 Ozanne-Smith J, Ashby K, Newstead S, Stathakis VZ, Clapperton A. Firearm related deaths: the impact of regulatory reform. Inj Prev. 2004;10:280-6. [pmid: 15470007].
66 Beautrais AL, Fergusson DM, Horwood LJ. Firearms legislation and reductions in firearm-related suicide deaths in New Zealand. Aust N Z J Psychiatry. 2006;40(3):253-9. Canterbury Suicide Project, Christchurch School of Medicine & Health Sciences, New Zealand. suicide@chmeds.ac.nz. [pmid: 16476153].
67 Prince MI, Thomas SH, James OF, Hudson M. Reduction in incidence of severe parac-etamol poisoning. Lancet. 2000;355:2047-8. [pmid: 10885358].
68 Turvill JL, Burroughs AK, Moore KP. Change in occurrence of paracetamol overdose in UK after introduction of blister packs. Lancet. 2000;355:2048-9.
69 Robinson D, Smith AM, Johnston GD. Severity of overdose after restriction of paraceta-mol availability: retrospective study. BMJ. 2000;321:926-7. [pmid: 11030678].
70 Sheen CL, Dillon JF, Bateman DN, Simpson KJ, MacDonald TM. Paracetamol-related deaths in Scotland, 1994–2000. Br J Clin Pharmacol. 2002;54:430-2. [pmid: 12392592].
71 Hughes B, Durran A, Langford NJ, Mutimer D. Paracetamol poisoning--impact of pack size restrictions. J Clin Pharm Ther. 2003;28:307-10. [pmid: 12911683].
72 Hawton K, Townsend E, Deeks J, Appleby L, Gunnell D, Bennewith O, et al. Effects of legislation restricting pack sizes of paracetamol and salicylate on self poisoning in the United Kingdom: before and after study. BMJ. 2001;322:1203-7. [pmid: 11358770].
73 Hawton K. United Kingdom legislation on pack sizes of analgesics: background, rationale, and effects on suicide and deliberate self-harm. Suicide Life Threat Behav. 2002;32:223-9. [pmid: 12374469].
74 Hawton K, Simkin S, Deeks J, Cooper J, Johnston A, Waters K, et al. UK legislation on analgesic packs: before and after study of long term effect on poisonings. BMJ. 2004;329:1076. [pmid: 15516343].
75 Morgan O, Griffiths C, Majeed A. Impact of paracetamol pack size restrictions on poisoning from paracetamol in England and Wales: an observational study. J Public Health (Oxf). 2005;27:19-24. [pmid: 15637104].
76 Morgan OW, Griffiths C, Majeed A. Interrupted time-series analysis of regulations to reduce paracetamol (acetaminophen) poisoning. PLoS Med 2007; 4:(4)e105 Department of Primary Care and Social Medicine, Imperial College London, United Kingdom. omorgan@bigfoot.com.
77 Donohoe E, Tracey J. Restrictions on sale of paracetamol in Ireland had no impact on the number of tablets ingested in acute deliberate overdose. J Toxicol Clin Toxicol. 2001;38:251.
78 Balit CR, Isbister GK, Peat J, Dawson AH, Whyte IM. Paracetamol recall: a natural experiment influencing analgesic poisoning. Med J Aust. 2002;176:162-5. [pmid: 11913916].
79 Kreitman N. The coal gas story. United Kingdom suicide rates, 1960–71. Br J Prev Soc Med. 1976;30:86-93. [pmid: 953381].
80 Kendell RE. Catalytic converters and prevention of suicides. Lancet. 1998;352:1525. [pmid: 9820310].
81 Amos T, Appleby L, Kiernan K. Changes in rates of suicide by car exhaust asphyxiation in England and Wales. Psychol Med. 2001;31:935-9. [pmid: 11459392].
82 Routley VH, Ozanne-Smith J. The impact of catalytic converters on motor vehicle exhaust gas suicides. Med J Aust. 1998;168:65-7. [pmid: 9469185].
83 Oliver RG, Hetzel BS. Rise and fall of suicide rates in Australia: relation to sedative availability. Med J Aust. 1972;2:919-23. [pmid: 4639963].
84 Whitlock FA. Suicide in Brisbane, 1956 to 1973: the drug-death epidemic. Med J Aust. 1975;1:737-43. [pmid: 239307].
85 Beautrais AL. Effectiveness of barriers at suicide jumping sites: a case study. Aust N Z J Psychiatry. 2001;35:557-62. [pmid: 11551268].
86 Motto JA. Newspaper influence on suicide. A controlled study. Arch Gen Psychiatry. 1970;23:143-8. [pmid: 5428298].
87 Green LW, Glasgow RE. Evaluating the relevance, generalization, and applicability of research: issues in external validation and translation methodology. Eval Health Prof. 2006;29:126-53. [pmid: 16510882].
88 Morgan O, Majeed A. Restricting paracetamol in the United Kingdom to reduce poisoning: a systematic review. J Public Health (Oxf). 2005;27:12-8. [pmid: 15590709].
89 Hawton K, Townsend E, Arensman E, Gunnell D, Hazell House Aea. Psychosocial and pharmacological treatments for deliberate self harm (Cochrane Review). The Cochran Library. 3. Oxford. Update Software. 2002.
90 Crawford MJ, Thomas O, Khan N, Kulinskaya E. Psychosocial interventions following self-harm: systematic review of their efficacy in preventing suicide. Br J Psychiatry. 2007;190:11-7. [pmid: 17197651].
91 Lester D. The effectiveness of suicide prevention centers: a review. Suicide Life Threat Behav. 1997;27:304-10. [pmid: 9357085].
92 Isacsson G, Rich CL. Antidepressant drug use and suicide prevention. Int Rev Psychiatry. 2005;17(3):153-62. Department of Clinical Neuroscience, Division of Psychiatry, Karolinska Institute, Karolinska University Hospital, Huddinge M59, S-141 86 Stock-holm, Sweden. Goran.Isaacson@cns.ki.se. [pmid: 16194786].
93 Baldessarini RJ, Tondo L, Davis P, Pompili M, Goodwin FK, Hennen J. Decreased risk of suicides and attempts during long-term lithium treatment: a meta-analytic review. Bipolar Disord. 2006;8:625-39. [pmid: 17042835].
94 Hennen J, Baldessarini RJ. Suicidal risk during treatment with clozapine: a meta-analysis. Schizophr Res. 2005;73:139-45. [pmid: 15653256].
95 Aguilar EJ, Siris SG. Do antipsychotic drugs influence suicidal behavior in schizophre -nia?. Psychopharmacol Bull. 2007;40:128-42. [pmid: 18007574].
96 Bryan CJ, Rudd MD. Advances in the assessment of suicide risk. J Clin Psychol. 2006;62:185-200. [pmid: 16342288].