# METHODS

## TOPIC DEVELOPMENT

This project was nominated by the Office of Research and Development for the Evidence Synthesis Project. Key questions were discussed and finalized during a conference call that included the Steering Committee of the Evidence Synthesis Project and the VA Greater Los Angeles project site director. The final key questions are:

1. What are the new or improved suicide prevention strategies (e.g. hotlines, outreach programs, peer counseling, treatment coordination programs, and new counseling approaches) that show promise for Veterans?
2. What solid evidence base supports the most promising strategies?
3. What evidence is still needed to establish various strategies as the most promising (framed as research questions to guide and focus continued research to expand knowledge regarding the effectiveness of suicide prevention approaches)?

## SEARCH STRATEGY

Mann et al. completed a systematic review of the literature on suicide prevention from 1966 through June 2005.^1^ As we scored this article well on those aspects of the Oxman-Guyatt Overview Quality Assessment Questionnaire9 and the AMSTAR Systematic Review Checklist10 that dealt with the rigor of the search and selection process, we judged the articles identified by this review as a suitable starting place for our own review. They searched MEDLINE, the Cochrane Library, and PsychINFO databases. We updated this using the same search strategy, starting from July 2005 through May 2008.

The search strategy is listed below:

DATABASES SEARCHED & TIME PERIOD COVERED: PubMed

June 2005 – May 2008

LIMITERS: ENGLISH

SEARCH STRATEGY:

Suicide/prevention and control

OR

suicide, attempted/prevention and control

OR

suicide AND (prevent*[tiab] OR depression OR health education OR health promotion OR public opinion OR mass screening OR family physicians OR medical education OR primary health care OR antidepressive agents OR psychotherapy OR schools OR adolescents OR methods OR firearms OR overdose OR poisoning OR gas poisoning OR mass media)

NOT

case report* OR editorial* OR letter

TOTAL RESULTS – 3,212+

+ references to “suicide cells” & “suicide genes” were manually removed and are not included in this number

In addition to our PubMed search, we performed reference mining of retrieved articles, references of prior reviews, and solicited articles from experts.