# INTRODUCTION

## BACKGROUND

Suicide is a major problem in public health. In the US suicide is roughly the 10^th^ leading cause of death, corresponding to about 30,000 deaths per year. Suicide is now understood as a multifactorial phenomenon, with biological, psychological, and social/environmental risk vulnerabilities and triggers. The majority of suicides–at least 90% by some studies in–the US implicate a psychiatric disorder, usually a mood disorder.1,2

US military veterans are a large population with multiple, and often significant risk factors for suicide. The Veterans Health Study, which screened 2160 male outpatients at Boston-area VA clinics, reported depressive symptoms in 31% of the sample, a rate more than twice that of the general population.4 A study of over 800,000 depressed veterans reported a suicide rate about 7 times higher than the baseline risk in the general population.5 The same study also showed that substance abuse elevated the suicide risk in depressed veterans. A recent report on the prevalence of mental health disorders in soldiers returning from the current Iraq conflict found clinician-identified mental health problems in 20% of active duty personnel, and in over 40% of National Guard and reserve personnel.6 Suicide in these newly discharged veterans has also received considerable political and media scrutiny.

The main problem confronting those working in suicide prevention is that while the absolute number of suicides in a population is cumulatively quite large, the risk of suicide to any given individual, even those with multiple risk factors, is by relative measures quite small. This problem is illustrated in an example in Gaynes et al.7 who show that for reasonable assumptions of sensitivity and specificity, a screening test for suicide risk would have a positive predictive value of 0.3% and generate an overwhelming number of false positives. These same factors complicate any attempt at constructing randomized clinical trials of suicide prevention efforts. It is widely recognized that the problem of accurate suicide prediction at the clinical level is currently an intractable one.3

In spite of the difficulties with prediction, structured approaches to suicide prevention have been developed. The multifactorial nature of the problem of suicide has required the adoption of a multifaceted approach to intervention, combining population-based screening and education, with more targeted efforts for those at above-baseline risk. These methods were reviewed by Mann et al.1 and their conceptual model will organize the interventions we review in this report (Figure 1).

Figure 1 Targets of Suicide Prevention Interventions from Mann et al.1

In their model life stressors and psychiatric disorders combine to produce suicidal ideation, which is modulated by impulsivity, hopelessness/pessimism, access to lethal means, and imitation, leading to the final suicidal act. The interventions correspond to different points in this causal network. The set of interventions, adapted from Mann et al., that are considered in this review appear in Table 1 and described in detail in the following.

Table 1 Set of interventions from Mann et al.1

Education and Awareness Programs
Primary Care Physicians
General Public/Population
Community or Organization Gatekeepers
Screening for individuals at high risk
Pharmacotherapy or ECT
Psychotherapy
Follow-up care for suicide attempts
Restriction of access to lethal means
Media reporting guidelines for suicide

Other Education and awareness programs can have various audiences; they can be aimed at primary care physicians to improve detection of mental health issues or significant stressors with the goal of referring to mental health clinicians for diagnosis and treatment, at a particular population (or the general public) to educate them about suicide and the availability of resources for getting help, and at nonclincian gatekeepers, such as medical clerks, chaplains, or military unit commanders, who as part of their work activities come into contact with large groups and who could, with improved training, provide education or identify those at high risk.

Screening programs for those at high risk target interventions towards those with known risk factors for suicide. These include patients who have previously expressed suicidal ideation or made suicide attempts, or those with mood disorders or substance abuse disorders, who are higher risk than the general population.

Mental health treatment is typically organized into biological therapies, including both pharmacotherapy (e.g., antidepressants), and electroconvulsive therapy (ECT), and psychosocial approaches, such as psychotherapy (e.g., cognitive-behavioral therapy), supportive counseling or treatment for substance abuse.

Because suicide attempts are known to be a strong predictor of future attempts (and completions), specific invention efforts have been directed to this high-risk population. Typically this involves tracking individuals after emergency room visits for suicide attempts, providing close mental health follow up, therapy, or case management.

Restriction of access to lethal means covers a variety of population-wide measures that limit the availability of commonly used methods of suicide. These include restricting access to highly lethal means (firearms through background checks, waiting periods, licensing laws, or bans, jumping by installing barriers on bridges), common means (limiting package sizes or configurations of pharmaceuticals used in overdose, most commonly acetaminophen), and other community or social interventions (such as changing the source and composition of domestic gas to have a lower carbon monoxide content, and requiring the installation of catalytic converters on all newly manufactured vehicles to reduce the level of carbon monoxide in the exhaust gas). An important issue in means restriction is whether reducing the availability of one mechanism will reduce the suicide rate overall, or merely shift suicides towards other available methods.

Media reporting guidelines are designed to address the problem of imitation or contagion: widely publicized suicides, especially of celebrities, are thought to temporarily increase the suicide rate, especially of suicides that mimic the reported mechanism. More information about the media and imitative suicides can be found in a recent review by Pirkis.8.

Suicide prevention programs, especially those designed for very large organizations such as military forces, or for entire nations, are typically multifaceted programs comprising a variety of different interventions just mentioned; most often the multifaceted programs combine population-based programs that use education and screening with more targeted interventions for those with identified risk factors.

Other factors not explicitly listed above, such as substance abuse, and homelessness, are also relevant because they affect impulsitivity or hopelessness, and are also obvious targets of both mental health and broader social interventions.

Because completed suicide is a very rare event in small samples, various approaches have been taken in assessing the efficacy of intervention programs. First, intermediate or proxy outcome measures can be used. Relevant outcomes would be decreases in depression rating scores, or decreased reports of suicidal ideation. However, the use of these measure greatly inflates the number of implicated studies for review – the examples mentioned would involve nearly all the published literature on the treatment of mood disorders – or involve subjective assessments of the strength of the suicidal ideation and whether the ideation was the precursor of an intended act or merely a means of communication to others or of obtaining hospital admission. Because of these concerns, the outcomes used in this report are suicide attempts, and completed suicides.

In this report we review the state of the evidence for suicide prevention, with a special focus on the military and veteran populations. The interventions are organized into the taxonomy presented above. The three key questions were:

1. What are the new or improved suicide prevention strategies (e.g. hotlines, outreach programs, peer counseling, treatment coordination programs, and new counseling approaches) that show promise for Veterans?
2. What solid evidence base supports the most promising strategies?
3. What evidence is still needed to establish various strategies as the most promising (framed as research questions to guide and focus continued research to expand knowledge regarding the effectiveness of suicide prevention approaches)?