# PEER REVIEW COMMENTS

Appendix D Peer Review Comments

Section | Comment | Change
General | Outcome information was collected for only three categories: “Attempters, Completers, SI.” The synthesis project does not address any literature demonstrating if suicide prevention strategies impact: a) the need for hospitalization, b) number of ER visits, c) patient and provider satisfaction, etc. | The scope of the report was set in consultation with the ESP Advisory Committee and the outcomes were restricted to the ones included in this report. These additional outcomes could be included in an update or new ESP report
General | The literature review was detailed but narrative, and it would be helpful to see the summation in a data table. It’s very difficult to find the “take home messages” amidst all the detail. There apparently were data collection forms in Appendix D. Would like to see data tables for the data collected in these forms to better understand the results of the synthesis project. | Summarizing the results of disparate studies is always a challenge. We have included Evidence Tables summarizing most of the data from the included studies in Appendix C. Each report section then also has a narrative summary, as does the report’s conclusion.
General | Are there any studies on suicide prevention related to this report that we have overlooked?: The use of telemedicine for suicide prevention | We reported all studies identified as of the search date. We found no studies reporting outcomes from telemedicine interventions.
General | The VA National Center for Suicide Prevention and the MIRECC in Denver may have at least some published data describing the impact of the recent VA national suicide prevention hotline. This would obviously be the most relevant information, yet there was no mention of this in the project synthesis. It would be helpful if the document states explicitly one way or another if there is any recent data to be factored from either of these VA suicide prevention centers, either in the literature, in press or otherwise. | We used standard search techniques to find published literature, and did not attempt to identify unpublished or not yet published results. We’ll check with VA to see if there is anything published abpout the impact of the VA hotline.
Executive Summary, Methods | even in this brief summary, it would be useful to list the inclusion critieria yielding studies below, e.g., interventions, controlled studies, outcomes limited to attempts, completed suicides?)) | We have added a list of the search criteria in the executive summary.
Introduction, Background | Section contains much useful information; some statements would benefit from references, to guide the interested reader—e.g., what is known or theorized about media-induced imitation or contagion? | We have added a reference to a recent review on media-induced imitation.
Methods, Study Selection | This exclusion makes sense but doesn’t seem to be consistently followed. I’ll note examples below. If interional, maybe further clarification of the exclusion here would be useful | Our original description in Study Selection was imprecise. We have added text to clarify the search criteria, especially with respect to exclusion of mental health interventions.
Methods, Grade | I may have missed it, but it’s not clear to me where these quantitative instructions are applied to the studies in this report. If in an appendix, might be useful to steer the reader to it here. | The quality assessment of individual articles appears in tables in Appendix C. The GRADE ratings were applied to sets of evidence taken together, and appear in the text of the results section.
Key Questions 1 & 2 | All of these studies are quite well described. This one, though, left me with a question. Did the study employ a chaplain to deliver a secular counseling/educational intervention? Or was there a religious component to the education? Seems basic to understanding the study/ | The article in question does not provide enough detail to allow us to accurately answer this question.
Key Questions 1 & 2 | Referring to Koons et al. This study would seem to be excluded as a “mental health intervention only”. Its foundational efficacy studies specifically addressed suicide. If there’s a reason to include it, consider clarifying critera? | See answer to item 8
Key Questions 1 & 2 | referring to Ilgen Also would seem to be excluded as a “mental health intervention only”. If SUD or ‘program’ features set it apart, consider clarifying criteria? | See answer to item 8
Key Questions 1 & 2 | referring to Gibbons Would seem to be excluded as a “mental health intervention only”. If reason is that the study addresses an induction effect rather than a treatment effect, consider clarifying here. | See answer to item 8
Key Questions 1 & 2 | referring to Webster et al. Not sure I understand, because it’s not clear to me how representative any one state is (of the country?) Consider listing states and characteristics, e.g., more rural, higher prevalence of alcoholism, etc.? | We have re-written the description of this study’s results to avoid the question of “representativeness.”
Limitations, Study Quality | I’m sure the authors know more about this than I do; I thought this work consistutes a ‘systematic review’ and that a ‘meta-analysis’ would be distinguished from this review by the pooling of data across studies. | This comment is correct, this synthesis is not a meta-analysis and we have changed the text to reflect that.
Executive Summary, Key Questions 1 & 2 | What about access to and treatment of mental health or sud disorders-does that reduce suicide – addiction treatment, clozapine, etc | See answer to item 8
Executive Summary, Key Question 3 | Perhaps a major statement here on defining terms is needed – this is really a problem in the literature. Define gesture, attempt, ideation, death ideation etc. | We have added more text highlighting the critical nature of such terminology for advancing the field.
Methods, Figure 1 | Alcohol and drug use isn’t listed as a factor involved in behavior –this seems like an oversight | We have added a comment about the role of substance abuse and other factors not explcitly appearing in the Mann conceptual model to the introduction.
Methods | Another target might be social situation – homelessness, employment (there is a strong correlation in the jobless rate and suicde rates) so programs like CWT or Supported employment might be important to mention. | Same answer as item 18.
Methods | How about those in mh care | See answer to item 8
Methods | Transition from inpatient to outpatient care – I believe there is data on a critical time intervention by lisa dixon on this issue | We found no study by Dixon reporting a direct effect on suicide attempts or completions.
Results, Literature Flow | It isn’t clear what this means: “ were rejected at title review as clearly irrelevant to the project” | If the title clearly indicated that the study did not report an outcome relevant to our search, then it was rejected. This is standard practice in systematic reviews and meta-analyses.
Key Questions 1 & 2 | The prospect study (M Bruce showed a reduction in suicide ideation when treating depression in primary care, should these type studys not be included? | We did not consider studies reporting changes in rates of suicidal ideation, only studies that reported direct effects on suicide attempts or completions.
Limitations | Probably worth saying in the summary: “Our review did not focus on purely menthal health interventions. These have been the subject of other reviews. Perhaps somewhat surprisingly given the role of depressive disorders as significant risk factors for suicide, the evidence in support of the use of antidepressants is rather weak” | See answer to item 8
General | However, I am at a loss to explain why the IMPACT study was discussed but the PROSPECT study was noted as excluded given the extremely similar study designs (perhaps because IMPACT included some VA sites?). | If the study reported including veterans, then it was included, but not otherwise. See item 8.
General | This manuscript is still at a developmental stage so I delineate that which I would like to see in a final version more than providing a peer review per se [interspersed with other editorial observations roughly in order of appearance]: | No reply needed.
Introduction | An initial discussion of known correlates of suicide and suicidality (manuscript leads off suggesting the primary one is substance abuse) and/or conceptual framework for approaching this topic | In the Introduction, we described the Mann review’s conceptual model in moderate detail, because we used its search strategy. Our goal was not to review existing conceptual frameworks or to develop new ones.
Results | Greater connection and discussion to policy issues and programs; at present it is a very dry list of vignettes from research papers | The results section lists in a narrative format the results of our search. The summary section contains some comments related to research and policy development.
Key Question 1 | Summary of strategies for key question #1 is largely absent | Questions 1 and 2 were answered together.
Results | Specific data from the quality review are not presented | The quality data appear in Appendix C for the RCTs and CCTs.
General | Page numbers end partway into the manuscript | This problem has been fixed.
General | Needs editing for consistency of tone and some substitution of colloquial or inappropriate word choices [e.g., ‘repertoire’, ‘more easily had’] | These phrases have been rewritten.
Executive Summary, Key Question 3 | Page 10, penultimate paragraph: would revise to “similar…profiles to the antemortem profiles of suicide completers.” | We have made the suggested change.
Introduction | Page 14, first paragraph: consider “nonclinician gatekeepers,” such as “medical clerks, chaplains, or military unit commanders,” since education programs may provide gatekeeper education to staff at medical facilities | We have made the suggested change.
Introduction | Page 14, last paragraph: brief summaries miss some elements (firearm purchase background checks and waiting periods; drug package configurations not just sizes) | We have made the suggested change.
General | Beautrais study: should describe the nature of the additional data; as it reads now it is not clear what distinction is being made in the last sentence | We have added a brief description of the additional data to clarify this point.
General | The objectives of the report are not clear. Why was this report commissioned? In response to what pressures? Several key questions were developed following a conference call (page 14). It is not clear who commissioned the Office of R&D for the Evidence Synthesis Project; why were these topics (i.e suicide screening) selected. What were the “key questions” responding to? Why was a key question formulated but not addressed at all in the review?? Therefore, in my opinion additional background might be helpful to better delineate whether the objectives and scope of the report were appropriate. On the other hand, the methods are clearly described. | As noted in the report, this topic was nominated by Office of Research and Development to the ESP Advisory Committee, and the Key Questions were developed by these two groups working together. The pressures leading to the nomination of this topic, other than VA’s concern for the mental health of the veteran population, are outside our scope.
General | I was impressed with the objectivity of the report. Studies are presented without bias. The strengths and weaknesses of the studies are briefly but clearly described. After each topic, the results of the relevant studies pertaining to that topic are summarized. These are strengths of the review. | No changes needed.
General | Are there any studies on suicide prevention related to this report that we have overlooked?: No to my knowledge. Critical studies that have influenced national VHA policy regarding suicide screening and intervention have been included. One possible criticism is that studies that have been pivotal should be identified as such and perhaps discussed more fully. An example might be the US Air Force Study from the BMJ (Knox et al, reference #14). | We agree the methodological advantages of the Knox study and have added extra detail about it.
Key Questions 1, 2, & 3 | This report is well constructed, well written and very helpful. It summarizes a broad range of studies, providing brief commentary in the form of summary statements. The report stops short of suggesting national guidelines or policy based upon the available data (i.e. evidence based recommendations), potentially a limitation as the authors are probably particularly well poised to do so after this thorough review. In fact, Key Question #1 directly asks this question and is left unanswered. The responses to Key Questions #1 and #2 are tentative and very general. For example, the response to Key Question #3 suggests that preliminary data be collected from the computerized medical record (page 8), without discussing any specific thoughts or recommendations as to what data should be collected and how. The use of the computer to help address Key Question #2 is not mentioned although the ability to track patients and ensure that they receive appropriate interventions is a very well recognized use of this resource. | The purpose of the report was to conduct a literature review, not report a policy analysis. We included a few general recommendations in the conclusion. Key Questions 1 and 2 were answered together.
Executive Summary | Page 8 suggest choosing another word than “Rare” in first sentence. Current debate in Congress, press, and email is why rates are so high for veterans. It might be the wrong tone to set. | We have removed that word and simplified the statement.
General | Are there any studies on suicide prevention related to this report that we have overlooked?: Is there any work from VISN19 MI-RECC which was designed to focus on suicide issues that might assist with this analysis? | We used standard search techniques to find published literature. We’ll check with the MIRECC to see if there is anything additional we might have missed.
General | This review demonstrated an embarrassing lack of evidence for Veterans in this critical and highly publicized topic. Research $$ should be directed toward remedying this. Perhaps a combination of the currently funded VISN 19 MIRECC and new studies? | No changes needed.
General | After reading this review and the synthesis review on depression, there seems a consistent theme in those studies having positive impact of additional or directed staff who build a “relationship” with the patient that plays the role of support and intervention as well as providing social contact for discussion, venting of issues, and advice. Perhaps the social isolation component should be studied as a variable that might have predictive value? | We agree that such factors are likely to be important. We have added a comment about this in the conclusion.
General | Consider studies involving telebuddy type devices, web access and response, etc. | No studies of such interventions were identified.