# EVIDENCE TABLES

Evidence Table 1 Studies Describing Suicide Prevention Interventions in Military Personnel and Veterans

Author, Year | Study Design | Country/Setting | Veteran/Military | Outcome | Intervention | Detailed Intervention | Results
James LC et al 1996^13^ | Cohort | US/Population & Other | No/Yes | Completers | Population/Organizational | 25th Infantry Division (Light) Suicide Prevention Program implementation beginning in 1992. This program incorporated warning signs and risk factors along with community education. | In the two years following complete implementation (1994) the suicide rate decreased to 3.
McDaniel WW et al. 1990^14^ | Cohort | US/Other | No/Yes | Attempters & SI | Organizational | This two year retrospective study examines a suicide prevention program at the training command center aimed at the instructors. The classes, provided in 1986 and then again from June 1987–January 1988, were targeted at informing instructors on how to recognize signs of distress and students at risk. | The average number of suicide attempts was 9.4 per 100,000 per month. The number of instructors who received training was negatively correlated (−0.65, p<0.001) with number of suicide attempts per month.
Knox KL et al. 2003^15^ | Interrupted Time Series | US/Population | No/Yes | Completers | Population/Organizational | To assess the impact of the US Air Force suicide prevention program implemented in 1996, this study looked at 5,260,292 air force personnel. The program aimed to reduce risk factors for suicide and enhance protective factors as well as increasing understanding of mental health and policies while decreasing the stigma of seeking mental health assistance. | The relative risk for suicide when comparing the pre-implementation population and post-implementation population was 0.67(95% CI: 0.57, 0.80). There was a 33% relative risk reduction for those in the post implementation group.
Jones DE et al. 2001^16^ | Observational | US/Population | No/Yes | Completers | Population | Existing resources (education in suicide awareness and life skills training, counseling, post-suicide interventions, and suicide incident reporting) were augmented with new training video using positive role models to increase detection and referral. | For Navy, suicide rate dropped to 9.2/100000, the lowest rate in 10 years. For the Marine Corps, the rate was 15.6/100000.
Kennedy CH et al. 2005^17^ | Cohort | US/Other | No/Yes | Attempters | Patient | This is a one year follow up on a gambling treatment program implemented in January 2003 as a part of the Substance Abuse Rehabilitation Program at the US Naval Hospital in Okinawa, Japan. There was 35 participants. | Prior to treatment 7 participants expressed suicidal ideation and 3 (8.5%) made suicide attempts related to their gambling. Post-implementation, no participants expressed suicidal ideation or attempted suicide.
Rozanov VA et al. 2002^18^ | Cohort | Ukraine/Population | No/Yes | Completers | Population/Organizational | This two year suicide prevention program, implemented in 2000, used training seminars for soldiers, professional officers, and commanders that spanned the course of one year. Brochures on suicide prevention were distributed to more than 2000 soldiers. | The average number of suicides per year between 1988 and 1999 was 32.6per 100,000. In 1999 the suicide rate was 74.7per 100,000. During the first year of the program there was no reported suicides and in the 2nd year there were 16.7 per 100,000 reported suicides.
Gordana DJ et al. 2007^19^ | Cohort | Serbia & Montenegro/Other | No/Yes | Completers | Organizational | Two year follow up on a Suicide Prevention Program, based on the U.S. Air force suicide prevention program, that was implemented in 2003. The program focused on early prevention and identification of those at increased risk of committing suicide. The long-term objective was modifying military-specific risk factors for suicide. The program was applied by selection, education, and motivation. | Suicides decreased from 15 in 2003 (pre-implementation) to 9 in 2004 and 7 in 2005. After one year of implementation, suicides decreased from 13 per 100,000 of military personnel to 5 per 100,000 military personnel.
Koons CR et al. 2001^22^ | RCT | UC/Psychiatric | Yes/No | Attempters & SI | Patient | Dialectical behavior therapy (DBT) in with borderline personality disorder. 28 women veterans were randomized to DBT or usual care groups. 20 patients (10 in each group) completed the treatment. | Patients in the DBT reported significantly greater decrease in depression (as measured by the BDI), suicidal ideation, and hopelessness than usual care patients.
Gibbons RD et al. 2007^24^ | Observational | US/Primary Care & Psychiatric | Yes/No | Attempters | Patient | Comparison of 226,866 patients in a VHA data set who were diagnosed with depression and had one of the following treatments: no antidepressant, SSRI, non-SSRI, tricyclic or combinations. | Odds ratio for comparing the SSRI treatment to the no antidepressant, non-SSRI and tricycle categories was 0.34 (95% CI: 0.31 to 0.38, p<0.0001).
Ilgen MA et al. 2007^23^ | Observational | US/Psychiatric | Yes/No | Attempters | Patient | This study followed 3733 veterans entering either a residential or outpatint substance abuse program. Data on suicide attempts were collected for 12 months prior to entry, during treatment and 12 months after entry. | During treatment, residential treatment was associated with a lower rate of suicide attempts than outpatient treatment. Predicting suicide attempts after drug abuse treatment was not significant for either setting.

SI: Suicidal Ideation

Evidence Table 2 RCT and CCTs Describing Suicide Interventions

Author, Year | Study Design/Setting | Sample Size Enrolled | Follow Up Time Points/Follow Up | Veterans/Military | Country/Mean Age | Eligibility Criteria | Quality Measurements | | | | Intervention | Duration of Treatment | Outcome | Adverse Events
Author, Year | Study Design/Setting | Sample Size Enrolled | Follow Up Time Points/Follow Up | Veterans/Military | Country/Mean Age | Eligibility Criteria | Described as Randomized | Eligibility Criteria Specified | Point estimates & measures of variability for primary outcomes variable | Co-interventions avoided | Intervention | Duration of Treatment | Outcome | Adverse Events
Author, Year | Study Design/Setting | Sample Size Enrolled | Follow Up Time Points/Follow Up | Veterans/Military | Country/Mean Age | Eligibility Criteria | Method of Randomization | Outcome Assessor Blinded | Point estimates & measures of variability for primary outcomes variable | Compliance acceptable | Intervention | Duration of Treatment | Outcome | Adverse Events
Author, Year | Study Design/Setting | Sample Size Enrolled | Follow Up Time Points/Follow Up | Veterans/Military | Country/Mean Age | Eligibility Criteria | Allocation Concealment | Care provider blinded | Randomized patients analyzed in group they were allocated to | Drop-out rate described | Intervention | Duration of Treatment | Outcome | Adverse Events
Author, Year | Study Design/Setting | Sample Size Enrolled | Follow Up Time Points/Follow Up | Veterans/Military | Country/Mean Age | Eligibility Criteria | Similarity at Baseline between groups | Patients Blinded | Randomized patients analyzed in group they were allocated to | Timing of Outcome Assessment Similar | Intervention | Duration of Treatment | Outcome | Adverse Events
Koons CJ et al. 2001^22^ | RCT/Psychiatric | 28 | 3 mths/NR 6 mths/20 | Yes/No | US/35 | Female veterans with borderline personality disorder | Yes | Yes | Yes | Yes | dialectical behavior therapy (DBT) and treatment as usual (TAU) | weekly meetings of 90 minutes each? | Attempters & SI | 30% DBT, 20% in TAU at post treatment reported self harm in
Koons CJ et al. 2001^22^ | RCT/Psychiatric | 28 | 3 mths/NR 6 mths/20 | Yes/No | US/35 | Female veterans with borderline personality disorder | Don’t Know | Yes | Yes | Yes | dialectical behavior therapy (DBT) and treatment as usual (TAU) | weekly meetings of 90 minutes each? | Attempters & SI | 30% DBT, 20% in TAU at post treatment reported self harm in
Koons CJ et al. 2001^22^ | RCT/Psychiatric | 28 | 3 mths/NR 6 mths/20 | Yes/No | US/35 | Female veterans with borderline personality disorder | Don’t Know | No | Yes | Yes | dialectical behavior therapy (DBT) and treatment as usual (TAU) | weekly meetings of 90 minutes each? | Attempters & SI | 30% DBT, 20% in TAU at post treatment reported self harm in
Koons CJ et al. 2001^22^ | RCT/Psychiatric | 28 | 3 mths/NR 6 mths/20 | Yes/No | US/35 | Female veterans with borderline personality disorder | Yes | No | Yes | Yes | dialectical behavior therapy (DBT) and treatment as usual (TAU) | weekly meetings of 90 minutes each? | Attempters & SI | 30% DBT, 20% in TAU at post treatment reported self harm in
Welu T 1977^25^ | RCT/Psychiatric | 120 | 4 mths/119 | No/No | US/29 | ED contact for suicide attempt | Yes | Yes | Yes | Don’t Know | follow up out- reach program by therapists | 4 month follow up outreach program | Attempters | at 4 months there were 3 repeated attempts in experimental group & 9 in control
Welu T 1977^25^ | RCT/Psychiatric | 120 | 4 mths/119 | No/No | US/29 | ED contact for suicide attempt | Yes | Don’t Know | Yes | Yes | follow up out- reach program by therapists | 4 month follow up outreach program | Attempters | at 4 months there were 3 repeated attempts in experimental group & 9 in control
Welu T 1977^25^ | RCT/Psychiatric | 120 | 4 mths/119 | No/No | US/29 | ED contact for suicide attempt | Don’t Know | No | Yes | Yes | follow up out- reach program by therapists | 4 month follow up outreach program | Attempters | at 4 months there were 3 repeated attempts in experimental group & 9 in control
Welu T 1977^25^ | RCT/Psychiatric | 120 | 4 mths/119 | No/No | US/29 | ED contact for suicide attempt | Don’t Know | No | Yes | Yes | follow up out- reach program by therapists | 4 month follow up outreach program | Attempters | at 4 months there were 3 repeated attempts in experimental group & 9 in control
Termansen PE et al. 1975^26^ | CCT/Psychiatric | 202 | 3 mths/128 | No/No | Canada/NR | ER presentation for suicide attempt | No | Yes | Yes | Don’t Know | 1. Mental health follow up 2. Phone follow up 3. Reassessment at 3 mths. 4. assessment at 3 mths. | 12 weeks | Attempters | Reattempt rate, 1: 2.2%, 2: 6.1%, 3: 22%, 4: 11.1%
Termansen PE et al. 1975^26^ | CCT/Psychiatric | 202 | 3 mths/128 | No/No | Canada/NR | ER presentation for suicide attempt | No | No | Yes | Don’t Know | 1. Mental health follow up 2. Phone follow up 3. Reassessment at 3 mths. 4. assessment at 3 mths. | 12 weeks | Attempters | Reattempt rate, 1: 2.2%, 2: 6.1%, 3: 22%, 4: 11.1%
Termansen PE et al. 1975^26^ | CCT/Psychiatric | 202 | 3 mths/128 | No/No | Canada/NR | ER presentation for suicide attempt | No | No | Yes | No | 1. Mental health follow up 2. Phone follow up 3. Reassessment at 3 mths. 4. assessment at 3 mths. | 12 weeks | Attempters | Reattempt rate, 1: 2.2%, 2: 6.1%, 3: 22%, 4: 11.1%
Termansen PE et al. 1975^26^ | CCT/Psychiatric | 202 | 3 mths/128 | No/No | Canada/NR | ER presentation for suicide attempt | Don’t Know | No | Yes | Yes | 1. Mental health follow up 2. Phone follow up 3. Reassessment at 3 mths. 4. assessment at 3 mths. | 12 weeks | Attempters | Reattempt rate, 1: 2.2%, 2: 6.1%, 3: 22%, 4: 11.1%
Allard R et al. 1992^27^ | RCT/Psychiatric | 150 | 12 mths/NR 18 mths/NR 24 mths/126 | No/No | Canada/NR | Seen in ED after suicide attempt | Yes | Yes | Yes | Don’t Know | a treatment plan, follow up visits, one home visit, reminder for missed appointments. Treatment could include meds or therapy | 18 therapy sessions & a home visit over 1 year | Attempters & Completers | 3 suicides in experimental & 1 in control
Allard R et al. 1992^27^ | RCT/Psychiatric | 150 | 12 mths/NR 18 mths/NR 24 mths/126 | No/No | Canada/NR | Seen in ED after suicide attempt | Don’t Know | Don’t Know | Yes | Yes | a treatment plan, follow up visits, one home visit, reminder for missed appointments. Treatment could include meds or therapy | 18 therapy sessions & a home visit over 1 year | Attempters & Completers | 3 suicides in experimental & 1 in control
Allard R et al. 1992^27^ | RCT/Psychiatric | 150 | 12 mths/NR 18 mths/NR 24 mths/126 | No/No | Canada/NR | Seen in ED after suicide attempt | Don’t Know | No | Yes | Yes | a treatment plan, follow up visits, one home visit, reminder for missed appointments. Treatment could include meds or therapy | 18 therapy sessions & a home visit over 1 year | Attempters & Completers | 3 suicides in experimental & 1 in control
Allard R et al. 1992^27^ | RCT/Psychiatric | 150 | 12 mths/NR 18 mths/NR 24 mths/126 | No/No | Canada/NR | Seen in ED after suicide attempt | Yes | No | Yes | Yes | a treatment plan, follow up visits, one home visit, reminder for missed appointments. Treatment could include meds or therapy | 18 therapy sessions & a home visit over 1 year | Attempters & Completers | 3 suicides in experimental & 1 in control
Chowdhury N et al. 1973^28^ | CCT/Psychiatric | 155 | 6 mths/NR | No/No | UK/NR | Hospital contact for deliberate self harm for repeat patients | No | Yes | Yes | Don’t Know | outpatient clinic, home visits, telephone hotline | 6 months from discharge | Attempters | 24% acts of parasuicide in treatment & 23% in control
Chowdhury N et al. 1973^28^ | CCT/Psychiatric | 155 | 6 mths/NR | No/No | UK/NR | Hospital contact for deliberate self harm for repeat patients | No | Don’t Know | Yes | Don’t Know | outpatient clinic, home visits, telephone hotline | 6 months from discharge | Attempters | 24% acts of parasuicide in treatment & 23% in control
Chowdhury N et al. 1973^28^ | CCT/Psychiatric | 155 | 6 mths/NR | No/No | UK/NR | Hospital contact for deliberate self harm for repeat patients | Don’t Know | No | No | Yes | outpatient clinic, home visits, telephone hotline | 6 months from discharge | Attempters | 24% acts of parasuicide in treatment & 23% in control
Chowdhury N et al. 1973^28^ | CCT/Psychiatric | 155 | 6 mths/NR | No/No | UK/NR | Hospital contact for deliberate self harm for repeat patients | Yes | No | No | Yes | outpatient clinic, home visits, telephone hotline | 6 months from discharge | Attempters | 24% acts of parasuicide in treatment & 23% in control
Gardner R et al. 1977^29^ | RCT/Hospital | 312 | 1 yr/273 | No/No | UK/NR | Patient admitted to hospital for self poisoning | Yes | Yes | Yes | Don’t Know | Inpatient assessment by medical vs. psychiatric team | Not reported. Assessment during following year. | Attempters & Completers | 10% repeat attempts for medical team, 13% repeat at- tempts for psychiatrist. 0% suicide for medical team, 0.4% for psychiatrist.
Gardner R et al. 1977^29^ | RCT/Hospital | 312 | 1 yr/273 | No/No | UK/NR | Patient admitted to hospital for self poisoning | Yes | Yes | Yes | Yes | Inpatient assessment by medical vs. psychiatric team | Not reported. Assessment during following year. | Attempters & Completers | 10% repeat attempts for medical team, 13% repeat at- tempts for psychiatrist. 0% suicide for medical team, 0.4% for psychiatrist.
Gardner R et al. 1977^29^ | RCT/Hospital | 312 | 1 yr/273 | No/No | UK/NR | Patient admitted to hospital for self poisoning | Don’t Know | No | Yes | Yes | Inpatient assessment by medical vs. psychiatric team | Not reported. Assessment during following year. | Attempters & Completers | 10% repeat attempts for medical team, 13% repeat at- tempts for psychiatrist. 0% suicide for medical team, 0.4% for psychiatrist.
Gardner R et al. 1977^29^ | RCT/Hospital | 312 | 1 yr/273 | No/No | UK/NR | Patient admitted to hospital for self poisoning | Don’t Know | No | Yes | Yes | Inpatient assessment by medical vs. psychiatric team | Not reported. Assessment during following year. | Attempters & Completers | 10% repeat attempts for medical team, 13% repeat at- tempts for psychiatrist. 0% suicide for medical team, 0.4% for psychiatrist.
Gibbons JS et al. 1978^30^ | RCT/Psychiatric & Other | 400 | 1 yr/400 | No/No | UK/NR | ED contact for deliberate self poisoning, not requiring immediate psychiatric treatment | Yes | Yes | Yes | Don’t Know | social worker to assist with task oriented problem solving | Not reported. Assessment at one year. | Attempters | 13.5 repeated self poisoning in treatment group & 14.5 in control
Gibbons JS et al. 1978^30^ | RCT/Psychiatric & Other | 400 | 1 yr/400 | No/No | UK/NR | ED contact for deliberate self poisoning, not requiring immediate psychiatric treatment | Don’t Know | Don’t Know | Yes | Don’t Know | social worker to assist with task oriented problem solving | Not reported. Assessment at one year. | Attempters | 13.5 repeated self poisoning in treatment group & 14.5 in control
Gibbons JS et al. 1978^30^ | RCT/Psychiatric & Other | 400 | 1 yr/400 | No/No | UK/NR | ED contact for deliberate self poisoning, not requiring immediate psychiatric treatment | Don’t Know | No | Yes | Yes | social worker to assist with task oriented problem solving | Not reported. Assessment at one year. | Attempters | 13.5 repeated self poisoning in treatment group & 14.5 in control
Gibbons JS et al. 1978^30^ | RCT/Psychiatric & Other | 400 | 1 yr/400 | No/No | UK/NR | ED contact for deliberate self poisoning, not requiring immediate psychiatric treatment | Don’t Know | No | Yes | Yes | social worker to assist with task oriented problem solving | Not reported. Assessment at one year. | Attempters | 13.5 repeated self poisoning in treatment group & 14.5 in control
Hawton K et al. 1981^31^ | RCT/Psychiatric | 96 | 1 yr/96 | No/No | UK/25.2 | Hospitalization for deliberate self poisoning | Yes | Yes | Yes | Don’t Know | outpatient vs. home based therapy | Maximum of 3 months, 1st 2 as frequent as needed | Attempters & SI | 10% repeated attempts in home- based, 15% in outpatients.
Hawton K et al. 1981^31^ | RCT/Psychiatric | 96 | 1 yr/96 | No/No | UK/25.2 | Hospitalization for deliberate self poisoning | Yes | Yes | Yes | No | outpatient vs. home based therapy | Maximum of 3 months, 1st 2 as frequent as needed | Attempters & SI | 10% repeated attempts in home- based, 15% in outpatients.
Hawton K et al. 1981^31^ | RCT/Psychiatric | 96 | 1 yr/96 | No/No | UK/25.2 | Hospitalization for deliberate self poisoning | Yes | No | Yes | Yes | outpatient vs. home based therapy | Maximum of 3 months, 1st 2 as frequent as needed | Attempters & SI | 10% repeated attempts in home- based, 15% in outpatients.
Hawton K et al. 1981^31^ | RCT/Psychiatric | 96 | 1 yr/96 | No/No | UK/25.2 | Hospitalization for deliberate self poisoning | Yes | No | Yes | Yes | outpatient vs. home based therapy | Maximum of 3 months, 1st 2 as frequent as needed | Attempters & SI | 10% repeated attempts in home- based, 15% in outpatients.
Hawton K et al. 1987^32^ | RCT/Psychiatric & Primary Care | 80 | 9 mths/65 | No/No | UK/29.3 | Hospitalized for overdose, not in need of formal psychiatric care | Yes | Yes | Yes | Don’t Know | brief problem oriented counseling | Not reported. Assessment at one year. | Attempters & Completers | 1 patient in counseling group committed suicide, 15.4% in general practitioner group repeated, 7.3% in counseling repeated
Hawton K et al. 1987^32^ | RCT/Psychiatric & Primary Care | 80 | 9 mths/65 | No/No | UK/29.3 | Hospitalized for overdose, not in need of formal psychiatric care | Don’t Know | Yes | Yes | Yes | brief problem oriented counseling | Not reported. Assessment at one year. | Attempters & Completers | 1 patient in counseling group committed suicide, 15.4% in general practitioner group repeated, 7.3% in counseling repeated
Hawton K et al. 1987^32^ | RCT/Psychiatric & Primary Care | 80 | 9 mths/65 | No/No | UK/29.3 | Hospitalized for overdose, not in need of formal psychiatric care | Don’t Know | No | Yes | Yes | brief problem oriented counseling | Not reported. Assessment at one year. | Attempters & Completers | 1 patient in counseling group committed suicide, 15.4% in general practitioner group repeated, 7.3% in counseling repeated
Hawton K et al. 1987^32^ | RCT/Psychiatric & Primary Care | 80 | 9 mths/65 | No/No | UK/29.3 | Hospitalized for overdose, not in need of formal psychiatric care | Yes | No | Yes | Yes | brief problem oriented counseling | Not reported. Assessment at one year. | Attempters & Completers | 1 patient in counseling group committed suicide, 15.4% in general practitioner group repeated, 7.3% in counseling repeated
Guthrie E et al. 2001^33^ | RCT/Psychiatric | 119 | 6 mths/95 | No/No | UK/31.2 | ED contact for deliberate self poisoning | Yes | Yes | Yes | Don’t Know | four sessions of psychodynamic interpersonal therapy in patient’s home | 4 weekly at home sessions | Attempters & Completers & SI | 9% repeated self-harm in intervention & 28% in control, no completers
Guthrie E et al. 2001^33^ | RCT/Psychiatric | 119 | 6 mths/95 | No/No | UK/31.2 | ED contact for deliberate self poisoning | Yes | Yes | Yes | Yes | four sessions of psychodynamic interpersonal therapy in patient’s home | 4 weekly at home sessions | Attempters & Completers & SI | 9% repeated self-harm in intervention & 28% in control, no completers
Guthrie E et al. 2001^33^ | RCT/Psychiatric | 119 | 6 mths/95 | No/No | UK/31.2 | ED contact for deliberate self poisoning | Don’t Know | No | Yes | Yes | four sessions of psychodynamic interpersonal therapy in patient’s home | 4 weekly at home sessions | Attempters & Completers & SI | 9% repeated self-harm in intervention & 28% in control, no completers
Guthrie E et al. 2001^33^ | RCT/Psychiatric | 119 | 6 mths/95 | No/No | UK/31.2 | ED contact for deliberate self poisoning | Yes | No | Yes | Yes | four sessions of psychodynamic interpersonal therapy in patient’s home | 4 weekly at home sessions | Attempters & Completers & SI | 9% repeated self-harm in intervention & 28% in control, no completers
Bennewith O et al. 2002^34^ | RCT/Primary Care | 1932 | 12 mths/1932 | No/No | UK/32.6 | Seen in ED for deliberate self harm | Yes | Yes | Yes | Don’t Know | letter from GP, use of guidelines for GP to use | 1 year after first self harm episode | Attempters | 211 repeat self-harm in intervention group & 189 in the control
Bennewith O et al. 2002^34^ | RCT/Primary Care | 1932 | 12 mths/1932 | No/No | UK/32.6 | Seen in ED for deliberate self harm | Don’t Know | Yes | Yes | Don’t Know | letter from GP, use of guidelines for GP to use | 1 year after first self harm episode | Attempters | 211 repeat self-harm in intervention group & 189 in the control
Bennewith O et al. 2002^34^ | RCT/Primary Care | 1932 | 12 mths/1932 | No/No | UK/32.6 | Seen in ED for deliberate self harm | Don’t Know | No | Yes | Yes | letter from GP, use of guidelines for GP to use | 1 year after first self harm episode | Attempters | 211 repeat self-harm in intervention group & 189 in the control
Bennewith O et al. 2002^34^ | RCT/Primary Care | 1932 | 12 mths/1932 | No/No | UK/32.6 | Seen in ED for deliberate self harm | Don’t Know | No | Yes | Yes | letter from GP, use of guidelines for GP to use | 1 year after first self harm episode | Attempters | 211 repeat self-harm in intervention group & 189 in the control
Clarke T et al. 2002^35^ | RCT/Other | 526 | 12 mths/467 | No/No | UK/33 | ED contact for deliberate self harm | Yes | Yes | Yes | Don’t Know | case management led by nurse practitioner | 1 year follow up after first admission | Attempters | 19 readmitted in treatment & 25 in control
Clarke T et al. 2002^35^ | RCT/Other | 526 | 12 mths/467 | No/No | UK/33 | ED contact for deliberate self harm | Yes | Don’t Know | Yes | Yes | case management led by nurse practitioner | 1 year follow up after first admission | Attempters | 19 readmitted in treatment & 25 in control
Clarke T et al. 2002^35^ | RCT/Other | 526 | 12 mths/467 | No/No | UK/33 | ED contact for deliberate self harm | Yes | No | Yes | Yes | case management led by nurse practitioner | 1 year follow up after first admission | Attempters | 19 readmitted in treatment & 25 in control
Clarke T et al. 2002^35^ | RCT/Other | 526 | 12 mths/467 | No/No | UK/33 | ED contact for deliberate self harm | Yes | No | Yes | Yes | case management led by nurse practitioner | 1 year follow up after first admission | Attempters | 19 readmitted in treatment & 25 in control
Motto JA et al. 2001^37^ | RCT/Psychiatric | 843 | 1 yr/843 5 yrs/843 15 yrs/843 | No/No | US/NR | Hospitalized for depression or suicidality | Yes | Yes | Yes | Don’t Know | follow up letter | 15 years from discharge | Completers | after 15 years there were 25 suicides in the contact group, & 26 in the no contact group
Motto JA et al. 2001^37^ | RCT/Psychiatric | 843 | 1 yr/843 5 yrs/843 15 yrs/843 | No/No | US/NR | Hospitalized for depression or suicidality | Don’t Know | Don’t Know | Yes | Don’t Know | follow up letter | 15 years from discharge | Completers | after 15 years there were 25 suicides in the contact group, & 26 in the no contact group
Motto JA et al. 2001^37^ | RCT/Psychiatric | 843 | 1 yr/843 5 yrs/843 15 yrs/843 | No/No | US/NR | Hospitalized for depression or suicidality | Don’t Know | No | Yes | No | follow up letter | 15 years from discharge | Completers | after 15 years there were 25 suicides in the contact group, & 26 in the no contact group
Motto JA et al. 2001^37^ | RCT/Psychiatric | 843 | 1 yr/843 5 yrs/843 15 yrs/843 | No/No | US/NR | Hospitalized for depression or suicidality | Don’t Know | No | Yes | Yes | follow up letter | 15 years from discharge | Completers | after 15 years there were 25 suicides in the contact group, & 26 in the no contact group
Morgan HG et al. 1993^38^ | RCT/Psychiatric | 212 | 1 yr/212 | No/No | UK/30.1 | Admission follow up episode of deliberate self harm | Yes | Yes | Yes | Don’t Know | “green card” offering easy access to psychiatrist on call | 1 year follow up after first admission | Attempters & Completers | No suicides occurred; 5 repeated self harm (serious threats) in experiment & 15 in control
Morgan HG et al. 1993^38^ | RCT/Psychiatric | 212 | 1 yr/212 | No/No | UK/30.1 | Admission follow up episode of deliberate self harm | Yes | Don’t Know | Yes | Don’t Know | “green card” offering easy access to psychiatrist on call | 1 year follow up after first admission | Attempters & Completers | No suicides occurred; 5 repeated self harm (serious threats) in experiment & 15 in control
Morgan HG et al. 1993^38^ | RCT/Psychiatric | 212 | 1 yr/212 | No/No | UK/30.1 | Admission follow up episode of deliberate self harm | Don’t Know | No | Yes | Yes | “green card” offering easy access to psychiatrist on call | 1 year follow up after first admission | Attempters & Completers | No suicides occurred; 5 repeated self harm (serious threats) in experiment & 15 in control
Morgan HG et al. 1993^38^ | RCT/Psychiatric | 212 | 1 yr/212 | No/No | UK/30.1 | Admission follow up episode of deliberate self harm | Yes | No | Yes | Yes | “green card” offering easy access to psychiatrist on call | 1 year follow up after first admission | Attempters & Completers | No suicides occurred; 5 repeated self harm (serious threats) in experiment & 15 in control
Evans MO et al. 1999^39^ | RCT/Other | 827 | 6 mths/827 | No/No | UK/33.3 | Hospitalization for deliberate self harm | Yes | Yes | Yes | Don’t Know | “green card” offering 24 hr crisis phone consultation | 6 months following discharge | Attempters | 2 suicides in “green card” group & 1 in control
Evans MO et al. 1999^39^ | RCT/Other | 827 | 6 mths/827 | No/No | UK/33.3 | Hospitalization for deliberate self harm | Yes | Yes | Yes | Don’t Know | “green card” offering 24 hr crisis phone consultation | 6 months following discharge | Attempters | 2 suicides in “green card” group & 1 in control
Evans MO et al. 1999^39^ | RCT/Other | 827 | 6 mths/827 | No/No | UK/33.3 | Hospitalization for deliberate self harm | Don’t Know | No | Yes | Yes | “green card” offering 24 hr crisis phone consultation | 6 months following discharge | Attempters | 2 suicides in “green card” group & 1 in control
Evans MO et al. 1999^39^ | RCT/Other | 827 | 6 mths/827 | No/No | UK/33.3 | Hospitalization for deliberate self harm | Yes | No | Yes | Yes | “green card” offering 24 hr crisis phone consultation | 6 months following discharge | Attempters | 2 suicides in “green card” group & 1 in control
Carter GL et al. 2005^40^ | RCT/Psychiatric | 772 | 12 mths/772 | No/No | Australia/NR | ED contact for deliberate self poisoning | Yes | Yes | Yes | Don’t Know | postcard sent at 1,2,3,4,6,8,10,12 months after discharge | 12 months | Attempters | 57 repeat self harm in intervention & 68 in control
Carter GL et al. 2005^40^ | RCT/Psychiatric | 772 | 12 mths/772 | No/No | Australia/NR | ED contact for deliberate self poisoning | Yes | Yes | Yes | Yes | postcard sent at 1,2,3,4,6,8,10,12 months after discharge | 12 months | Attempters | 57 repeat self harm in intervention & 68 in control
Carter GL et al. 2005^40^ | RCT/Psychiatric | 772 | 12 mths/772 | No/No | Australia/NR | ED contact for deliberate self poisoning | Yes | NA | Yes | Yes | postcard sent at 1,2,3,4,6,8,10,12 months after discharge | 12 months | Attempters | 57 repeat self harm in intervention & 68 in control
Carter GL et al. 2005^40^ | RCT/Psychiatric | 772 | 12 mths/772 | No/No | Australia/NR | ED contact for deliberate self poisoning | Yes | No | Yes | Yes | postcard sent at 1,2,3,4,6,8,10,12 months after discharge | 12 months | Attempters | 57 repeat self harm in intervention & 68 in control
Waterhouse J et al. 1990^43^ | RCT/Primary Care & Hospital | 99 | 1 wk/NR 16 wk/NR | No/No | UK/NR | ED contact for parasuicidal act by self poisoning | Yes | Yes | Yes | Don’t Know | hospitalization | 16 months | Attempters & SI | at 16 weeks a total of 3 admitted & 4 discharged patients repeated parasuicide
Waterhouse J et al. 1990^43^ | RCT/Primary Care & Hospital | 99 | 1 wk/NR 16 wk/NR | No/No | UK/NR | ED contact for parasuicidal act by self poisoning | Yes | No | Yes | Don’t Know | hospitalization | 16 months | Attempters & SI | at 16 weeks a total of 3 admitted & 4 discharged patients repeated parasuicide
Waterhouse J et al. 1990^43^ | RCT/Primary Care & Hospital | 99 | 1 wk/NR 16 wk/NR | No/No | UK/NR | ED contact for parasuicidal act by self poisoning | Don’t Know | No | Yes | Don’t Know | hospitalization | 16 months | Attempters & SI | at 16 weeks a total of 3 admitted & 4 discharged patients repeated parasuicide
Waterhouse J et al. 1990^43^ | RCT/Primary Care & Hospital | 99 | 1 wk/NR 16 wk/NR | No/No | UK/NR | ED contact for parasuicidal act by self poisoning | Yes | No | Yes | Yes | hospitalization | 16 months | Attempters & SI | at 16 weeks a total of 3 admitted & 4 discharged patients repeated parasuicide
Unutzer J et al. 2006^45^ | RCT/Primary Care | 1801 | 2 yrs/NR | Yes/No | US/71.2 | Elderly with depression | Yes | Yes | Yes | Don’t Know | collaborative care program, including a depression case manager in primary care clinic | 12 months | Completers & SI | No completed suicides during 2 year follow up
Unutzer J et al. 2006^45^ | RCT/Primary Care | 1801 | 2 yrs/NR | Yes/No | US/71.2 | Elderly with depression | Yes | Yes | Yes | Don’t Know | collaborative care program, including a depression case manager in primary care clinic | 12 months | Completers & SI | No completed suicides during 2 year follow up
Unutzer J et al. 2006^45^ | RCT/Primary Care | 1801 | 2 yrs/NR | Yes/No | US/71.2 | Elderly with depression | Yes | No | Yes | Don’t Know | collaborative care program, including a depression case manager in primary care clinic | 12 months | Completers & SI | No completed suicides during 2 year follow up
Unutzer J et al. 2006^45^ | RCT/Primary Care | 1801 | 2 yrs/NR | Yes/No | US/71.2 | Elderly with depression | Yes | No | Yes | Yes | collaborative care program, including a depression case manager in primary care clinic | 12 months | Completers & SI | No completed suicides during 2 year follow up
Mishara BL et al. 2005^46^ | CCT/Other | 120 | 2 mths/120 6 mths/120 | No/No | Canada/NR | Family friend (of suicidal men) who called suicide hotline | No | Yes | Yes | Don’t Know | family friend of suicidal men were assigned to one of four programs | post test after 2 months with 6 month follow up | Attempters | 22.0% attempt rate at entry, 10.6% at 2 mo., 2.7% at 6 mo.
Mishara BL et al. 2005^46^ | CCT/Other | 120 | 2 mths/120 6 mths/120 | No/No | Canada/NR | Family friend (of suicidal men) who called suicide hotline | No | No | Yes | Yes | family friend of suicidal men were assigned to one of four programs | post test after 2 months with 6 month follow up | Attempters | 22.0% attempt rate at entry, 10.6% at 2 mo., 2.7% at 6 mo.
Mishara BL et al. 2005^46^ | CCT/Other | 120 | 2 mths/120 6 mths/120 | No/No | Canada/NR | Family friend (of suicidal men) who called suicide hotline | Don’t Know | No | Don’t Know | Yes | family friend of suicidal men were assigned to one of four programs | post test after 2 months with 6 month follow up | Attempters | 22.0% attempt rate at entry, 10.6% at 2 mo., 2.7% at 6 mo.
Mishara BL et al. 2005^46^ | CCT/Other | 120 | 2 mths/120 6 mths/120 | No/No | Canada/NR | Family friend (of suicidal men) who called suicide hotline | Don’t Know | No | Don’t Know | Yes | family friend of suicidal men were assigned to one of four programs | post test after 2 months with 6 month follow up | Attempters | 22.0% attempt rate at entry, 10.6% at 2 mo., 2.7% at 6 mo.

Evidence Table 3 Studies Describing Interventions Restricting the Access to Firearms

Author, Year | Study Design | Country/Setting | Veteran/Military | Legislation | Study Period | Outcome | Results
Loftin C et al. 1991^47^ | Interrupted Time Series | US/Population | No/No | District of Columbia’s Firearms Control Regulations Act 1976 | 1968–1987 | Mean number of suicides per month | Suicides using firearms decreased from 2.6 per month to 2.0 per month (p=.005). Non-firearm related suicides did not experience a decrease of similar magnitude.
Ludwig J et al. 2000^48^ | Interrupted Time Series | US/Population | No/No | Brady Handgun Violence Prevention Act, 1994 | 1985–1997 | Total suicide rates per 100,000 of population for adults (≥21 years and ≥55 years) controlling for age, race, poverty and income levels, urban residence, and alcohol consumption, the effected states (32 states where Brady handgun act was implemented) | Firearm suicide rates declined by 0.32 (95% CI: − 0.73, 0.20) for adults over 21 years old. For adults 55 or older suicide rates declined by 0.92 (95% CI: − 1.43, −0.42, p<.05).
Lott JR et al. 2001^49^ | Interrupted Time Series | US/Population | No/No | State Safe-Storage laws passed between October 1,1989 through January 1,1996 | 1979–1996 | Comparison of suicide rates, accidental deaths and crimes in states with and without Safe-Storage laws | Regression estimates were not statistically significant from 0 or from each other with and without including control variables. Thus the gun laws did not seem to have a statistically significant effect on suicide rates.
Rosengart M et al. 2005^50^ | Interrupted Time Series | US/Population | No/No | Multi-State: “Shall issue” (concealed weapons), minimum age of private purchase 21, minimum age of private possession 21, on gun per month, Junk gun ban | 1979–1998 | A cross sectional time series study of firearm suicides and homicides | None of the 5 laws were associated with a statistically significant change in firearm suicide rates.
Webster et al. 2004^51^ | Interrupted Time Series | US/Population | No/No | State and federal Child Access Prevention laws (requiring safe storage) | 1976–2001 | Number of total suicides per 100,000 and methods used for youth between 14 to 20 years old. | Of the 63,954 suicides between 1976–2001, 62% were committed with firearms. Firearm suicides increased from 2.6 in 1976 to a high of 5.7 in 1994. They quickly decreased to 2.5 in 2001. For youth between 14–17 child access prevention laws at the state level are associated with a 10.8% decrease in firearm suicides (RR, 0.89; 95% CI: 0.83–0.96). For adults between 18–20 state child access prevention laws are associated with a 11.1% decrease in suicides from firearms (RR, 0.89; 95% CI: 0.85–0.93).
Rich CL et al. 1990^52^ | Interrupted Time Series | Canada & US/Population | No/No | 1978 Criminal Code of Canada | 1973–1983 | Number of suicides in Ontario and Toronto and method of suicide for Toronto | The mean percent of suicides by firearms decreased significantly after the legislation went into effect (23.2% to 16.2%, difference 7%, p<0.0001). The total number of suicides did not significantly decrease.
Carrington PJ et al. 1994^53^ | Interrupted Time Series | Canada/Population | No/No | 1978 Criminal Code of Canada | 1965–1977 | Mean suicide rates per 100,000 and trends. | The suicide rate did not change significantly from the 5 years before and the 5 years after the 1978 gun control law (13.5 to 12.8, p=0.12). Regression analysis found no slope for the 5 years following the legislation.
Lester D et al. 1993^54^ | Interrupted Time Series | Canada/Population | No/No | Canada’s Criminal Law Amendment Act of 1977 (Bill C-51) | 1969–1985 | Annual suicide rates per 100,000 by all methods. | Suicide by firearm rates decreased after Bill C-51 (4.27 to 2.09, p=0.05). But the total suicide rate increased, suggesting that people turned to other methods.
Lester D et al. 1994^55^ | Interrupted Time Series | Canada & US/Population | No/No | Comment on assertion that Bill C-51 did not lessen suicide rates | 1969–1991 | Change in suicide rates for the period following the 1977 Bill C-51. | Before the passage of Bill C-51, firearm suicide rate was increasing (simple linear regression slope, b= 0.608, p=0.01), as were the total suicide rate and suicide rate from other methods. From 1978 to 1985 the overall suicide rate did not change and the rate by other methods did not change. The percentage of suicides by firearms did decrease (b= − 0.574, p=0.03).
Leenaars AA et al. 1996^56^ | Interrupted Time Series | Canada/Population | No/No | Canada’s Criminal Law Amendment Act of 1977 (Bill C-51) | 1969–1985 | Suicide rates before (1969– 1976) and after (1978–1985) the enactment of Bill C-51 | Suicide rates by firearms decreased significantly (p<0.05) after the passage of Bill C-51. Also the percentage of suicides by firearms also significantly decreased.
Lester D et al. 2001^57^ | Interrupted Time Series | Canada/Population | No/No | Canada’s Criminal Law Amendment Act of 1977 (Bill C-51) | 1970–1995 | Firearm suicide and homicide rates per 100,000 | The correlation between year and the percentage of suicides and homicides by firearms is − 0.86 (one-tailed p<0.001).
Leenaars AA et al. 1997^58^ | Observational | Canada/Population | No/No | Canada’s Criminal Law Amendment Act of 1977 (Bill C-51) | 1969–1985 | Suicide and homicide rates per 100,000 before and after Bill C-51 was passed | The mean annual number suicides decreased for those in the following age groups 15–24 (p<0.001), 35–64 (p<0.05), and 75 and over (p<0.01). Prior to the law the rate of suicides was increasing (regression line slope = 0.16) where as after the law went into effect the rate began to decrease (regression line slope = −0.13).
Leenaars AA et al. 2003^59^ | Interrupted Time Series | Canada/Population | No/No | Canada’s Criminal Law Amendment Act of 1977 (Bill C-51) | 1969–1985 | increase or decrease Suicide rates compared from before and after the 1977 Bill C-51. | Least squares regression showed that the introduction of the Bill had no statistically significant in the rate of suicides, overall or by firearms. However the Bill had a negative effect on the slope of the line, thus the Bill decreased the trend in suicide rates.
Bridges FS 2004^60^ | Interrupted Time Series | Canada/Population | No/No | Canadian Bill C-17 | 1984–1998 | Total suicide and homicide rates per 100,000, as well as methods, before and after Bill C-17. | The mean annual number of suicides significantly decreased from the first 7 year period to the 7 years following instatement of the Bill (4.09 to 3.17, p=.001). The rates by other methods increased significantly (9.02 to 9.76, p=.01). The total average number of suicides did not significantly differ between the 2 study periods (13.11 to 12.93).
Chung AH et al 2005^61^ | Interrupted Time Series | Canada/Population | No/No | Canadian Bill C-17 | 1979–1999 | Suicide rates and methods for youth between the ages of 15–19 before and after Bill C-17. | The percent of suicide by firearms decreased from 55% in 1979 to 25% in 1999. Death by other means increased during this time. The overall rate of suicides did not decrease.
Snowdon J et al. 1992^62^ | Observational | Australia/Population | No/No | Several? | 1968–1989 | Suicide rates per 100,000 by gender, State, age and residence. | The mean rate of firearm suicides was 6.13 for men and 0.43 for women (p<0.005).
Chapman S et al. 2006^63^ | Interrupted Time Series | Australia/Population | No/No | 1996 gun law reform, following the 1996 firearm massacre in Tasmania | 1979–2003 | Changes in trends of total firearm suicides and suicides per 100,000 of population | Before 1996, annual average of 491.7 firearm suicides. From 1997 to 2003, annual average of 246.6 firearm suicides.
Cantor CH et al. 1995^64^ | Observational | Australia/Population | No/No | Weapons Act 1990 (Qld) | 1990–1993 | Firearm suicide mean annual rates per 100,000 and method for different geographical areas two years before and two years after the legislation went into effect | Suicide rates decreased in metropolitan (3.6 to 2.3) and provincial areas (5.2 to 3.1) (p<0.05). The mean annual rate per 100,000 for rural areas was about double that of metropolitan and provincial areas. This rate did not decrease after the legislation. There was also a significant decrease in suicide rates among men and adults between 15 and 29 years old.
Ozanne-Smith J et al 2004^65^ | Interrupted Time Series | Australia/Population | No/No | Victoria Response (1988) and Firearms Act of 1996 | 1979–2000 | Following gun control regulations, death rates, trends, and ownership in Victoria and Australia. | The overall death rate decreased for Australia (−3.9%; 95% CI: −4.8% ro −3.1%) and Victoria(−4.9% 95% CI: −5.9, −3.9) from 1979 – 2000. Significant decreases in firearm related suicides were seen in Victoria. Suicides by firearms dropped by 54.5% from 1979 to 2000.
Beautrais A et al. 2006^66^ | Interrupted Time Series | New Zealand/Population | No/No | Amendment to the Arms Act, 1992 | 1985–2002 | Age-specific suicide rates per 100,000 of population for firearm and Non-firearm related suicides | For youths (15–24 years), firearm suicides were reduced by 39% in the 3 year implementation period and decreased 66% in the 5 year post-implementation period. For adults (25+ years) firearm suicides decreased by 25% in the 3 year implementation period and decreased by 39% in the 5 year post-implementation period.