# EXCLUDED STUDIES

## EXCLUDED AFTER INITIAL REVIEW

### No Intervention

Cooper SL, Lezotte D, Jacobellis J, Diguiseppi C. Does availability of mental health resources prevent recurrent suicidal behavior? An ecological analysis. Suicide Life Threat Behav. 2006;36(4):409-17. [pmid: 16978095].
Ettlinger RW. Suicides in a groupd of patients who had previously attempted suicide. Acta Psychiatr Scand. 1964;40:363-78. [pmid: 14325801].
Greer S, Lee HA. Subsequent progress of potentially lethal attempted suicides. Acta Psychiatr Scand. 1967;43(4):361-71. [pmid: 5582387].
Kessel N, McCulloch W. Repeated acts of self-poisoning and self-injury. Proc R Soc Med. Feb. 1966;59(2):89-92. [pmid: 5906758].
Shah A, Bhat R. Are elderly suicide rates improved by increased provision of mental health service resources? A cross-national study. Int Psychogeriatr. 2008:1-8.

### Foreign Language

Nielsen AS, Nielsen B. Pattern of choice in preparation of attempted suicide by poisoning--with particular reference to changes in the pattern of prescriptions. Ugeskr Laeger. Jul 6. 1992;154(28):1972-6. [pmid: 1354904].
Rueegsegger P. Attempted suicide. Clinical statistically and catamnestic studies of 132 attempted suicide patients in Basle University Psychiatric Clinic. 1963;146:81-104.

### Duplicate Data

Bateman A, Fonagy P. Treatment of borderline personality disorder with psychoanalytically oriented partial hospitalization: an 18-month follow-up. Am J Psychiatry. Jan. 2001;158(1):36-42. [pmid: 11136631].
McMain S. Dialectic behaviour therapy reduces suicide attempts compared with non-behavioural psychotherapy in women with borderline personality disorder. Evid Based Ment Health. 2007;10(1):18. [pmid: 17255387].
World Health Organization (WHO). For which strategies of suicide prevention is there evidence of effectiveness?. World Health Organitzation. Health Evidence Network. 2004.

### Review or Meta-analysis

Althaus D, Hegerl U. The evaluation of suicide prevention activities: state of the art. World J Biol Psychiatry. Oct. 2003;4(4):156-65. [pmid: 14608586].
Anderson M, Jenkins R. The challenge of suicide prevention - an overview of national strategies. Disease Management & Health Outcomes. 2005:13245-53.
Baldessarini RJ, Tondo L, Davis P, Pompili M, Goodwin FK, Hennen J. Decreased risk of suicides and attempts during long-term lithium treatment: a meta-analytic review. Bipolar Disord. 2006;8(5 Pt 2):625-39. [pmid: 17042835].
Baldessarini RJ, Tondo L, Strombom IM, Dominguez S, Fawcett J, Licinio J, Oquendo MA, Tollefson GD, Valuck RJ, Tohen M. Ecological studies of antidepressant treatment and suicidal risks. Harv Rev Psychiatry. 2007;15(4):133-45. [pmid: 17687708].
Beautrais A, Fergusson D, Coggan C, Collings C, Doughty C, Ellis P, Hatcher S, Horwood J, Merry S, Mulder R, Poulton R, Surgenor L. Effective strategies for suicide prevention in New Zealand: a review of the evidence. N Z Med J. 2007;120(1251):U2459. [pmid: 17384687].
Boscarino JA. External-cause mortality after psychologic trauma: the effects of stress exposure and predisposition. Compr Psychiatry. 2006;47(6):503-14. [pmid: 17067875].
Chan J, Draper B, Banerjee S. Deliberate self-harm in older adults: a review of the literature from 1995 to 2004. Int J Geriatr Psychiatry. 2007;22(8):720-32. [pmid: 17310495].
Cipriani A, Pretty H, Hawton K, Geddes JR. Lithium in the prevention of suicidal behavior and all-cause mortality in patients with mood disorders: a systematic review of randomized trials. Am J Psychiatry. 2005;162(10):1805-19. [pmid: 16199826].
Conwell Y, Thompson C. Suicidal behavior in elders. Psychiatr Clin North Am. 2008;31(2):333-56. [pmid: 18439452].
Crawford MJ, Thomas O, Khan N, Kulinskaya E. Psychosocial interventions following self-harm: systematic review of their efficacy in preventing suicide. Br J Psychiatry. Jan. 2007;190:11-7. [pmid: 17197651].
Daigle MS. Suicide prevention through means restriction: assessing the risk of substitution. A critical review and synthesis. Accid Anal Prev. 2005;37(4):625-32. [pmid: 15949453].
Dew MA, Bromet EJ, Brent D, Greenhouse JB. A quantitative literature review of the effectiveness of suicide prevention centers. J Consult Clin Psychol. Apr. 1987;55(2):239-44. [pmid: 3571680].
Diekstra RFW. The prevention of suicidal behaviour: evidence for the efficacy of clinical and community based programs. Int J Ment Health. 1992;21(3):69-87.
Gaynes BN, West SL, Ford CA, Frame P, Klein J, Lohr KN. Screening for suicide risk in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. May 18. 2004;140(10):822-35. [pmid: 15148072].
Goldney RD. Suicide prevention is possible: a review of recent studies. Archives of Suicide Research. 1998;4:329-339.
Gunnel D, Frankel S. Prevention of suicide: aspirations and evidence. BMJ. 1994;308:1227-1233. [pmid: 8080520].
Guo B, Scott A, Bowkers S. Suicide Prevention Strategies: Evidence from Systematic Reviews. Alberta Heritage Foundation for Medical Research Health Technology Assessment.
Guzzetta F, Tondo L, Centorrino F, Baldessarini RJ. Lithium treatment reduces suicide risk in recurrent major depressive disorder. J Clin Psychiatry. 2007;68(3):380-3. [pmid: 17388706].
Hawkins LC, Edwards JN, Dargan PI. Impact of restricting paracetamol pack sizes on paracetamol poisoning in the United Kingdom: a review of the literature. Drug Saf. 2007;30(6):465-79. [pmid: 17536874].
Hawton K, Townsend E, Arensman E, Gunnell D, Hazell P, House A, et al. Psychosocial and pharmacological treatments for deliberate self harm (Cochrane Review). The Cochran Library. 3. 2002. Oxford. Update Software. 2002.
Heisel MJ. Suicide and its prevention among older adults. Can J Psychiatry. 2006;51(3):143-54. [pmid: 16618005].
Hirsch JK. A review of the literature on rural suicide: risk and protective factors, incidence, and prevention. Crisis. 2006;27(4):189-99. [pmid: 17219751].
Hirsch SR, Walsh C, Draper R. Parasuicide. A review of treatment interventions. J Affect Disord. Dec. 1982;4(4):299-311. [pmid: 6298293].
Isacsson G, Rich CL. Antidepressant drug use and suicide prevention. Int Rev Psychiatry. 2005;17(3):153-62. [pmid: 16194786].
Lester D. The effectiveness of suicide prevention centers: a review. Suicide Life Threat Behav. Fall. 1997;27(3):304-10. [pmid: 9357085].
Links PS, Hoffman B. Preventing suicidal behaviour in a general hospital psychiatric service: priorities for programming. Can J Psychiatry. 2005;50(8):490-6. [pmid: 16127967].
Mackenzie M, Blamey A, Halliday E, Maxwell M, McCollam A, McDaid D, MacLean J, Woodhouse A, Platt S. Measuring the tail of the dog that doesn’t bark in the night: the case of the national evaluation of Choose Life (the national strategy and action plan to prevent suicide in Scotland). BMC Public Health. 2007:7146.
Mann JJ, Apter A, Bertolote J, Beautrais A, Currier D, Haas A, Hegerl U, Lonnqvist J, Malone K, Marusic A, Mehlum L, Patton G, Phillips M, Rutz W, Rihmer Z, Schmidtke A, Shaffer D, Silverman M, Takahashi Y, Varnik A, Wasserman D, Yip P, Hendin H. Suicide prevention strategies: a systematic review. JAMA. Oct 26. 2005;294(16):2064-74. [pmid: 16249421].
Moller HJ. Evidence for beneficial effects of antidepressants on suicidality in depressive patients: a systematic review. Eur Arch Psychiatry Clin Neurosci. 2006;256(6):329-43. [pmid: 16783501].
Morgan O, Majeed A. Restricting paracetamol in the United Kingdom to reduce poisoning: a systematic review. J Public Health (Oxf). Mar. 2005;27(1):12-8. [pmid: 15590709].
NHS Centre for Reviews and Dissemination. Deliberate self-harm. Effective Health Care. 1998;4(6):1-12.
Pignone MP, Gaynes BN, Rushton JL, Burchell CM, Orleans CT, Mulrow CD, Lohr KN. Screening for depression in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. May 21. 2002;136(10):765-76. [pmid: 12020146].
Pinkis J, Blood W, Beautrais A, et al. Media guidelines on the reporting of suicide. Crisis. 2006;27(2):82-7. [pmid: 16913330].
Rehkopf DH, Buka SL. The association between suicide and the socio-economic characteristics of geographical areas: a systematic review. Psychol Med. 2006;36(2):145-57. [pmid: 16420711].
Ritchie EC, Keppler WC, Rothberg JM. Suicidal admissions in the United States military. Mil Med. Mar. 2003;168(3):177-81. [pmid: 12685680].
Rodgers PL, Sudak HS, Silverman MM, Litts DA. Evidence-based practices project for suicide prevention. Suicide Life Threat Behav. Apr. 2007;37(2):154-64. [pmid: 17521269].
Safer DJ, Zito JM. Do antidepressants reduce suicide rates?. Public Health. 2007;121(4):274-7. [pmid: 17316717].
Seguin M, Lesage AD, Turecki G, et al. Research project on deaths by suicide in New Brunswick between April 2002 and May 2003. Douglas Hospital Research Centre and New Brunswick Department of Health. 2005.
Staal MA. The assessment and prevention of suicide for the 21st century: the Air Force’s community awareness training model. Mil Med. Mar. 2001;166(3):195-8. [pmid: 11263015].
Stander VA, Hilton SM, Kennedy KR, Robbins DL. Surveillance of completed suicide in the Department of the Navy. Mil Med. Apr. 2004;169(4):301-6. [pmid: 15132234].
van der Sande R, Buskens E, Allart E, van der Graaf Y, van Engeland H. Psychosocial intervention following suicide attempt: a systematic review of treatment interventions. Acta Psychiatr Scand. Jul. 1997;96(1):43-50. [pmid: 9259223].

### No Outcome of Interest or Usable Outcome

Preventing patient suicide. Healthc Hazard Manage Monit. 2007;21(1):1-8.
S-kit Suicide prevention local implementation framework: A strategic multi-agency toolkit aimed at saving lives. National Institute for Mental Health in England, Care Services Improvement Partnership.
Aguilar EJ, Siris SG. Do antipsychotic drugs influence suicidal behavior in schizophrenia?. Psychopharmacol Bull. 2007;40(3):128-42. [pmid: 18007574].
Akroyd S, Wyllie J. Impacts of National Media Campaign to Counter Stigma and Discriminantion Associated with Mental Illness: Survey 4. Wellington, New Zealand. New Zealand Ministry of Health. 2002. Publication 9-20-0004.
Anderson M, Jenkins R. The national suicide prevention strategy for England: the reality of a national strategy for the nursing profession. J Psychiatr Ment Health Nurs. 2006;13(6):641-50. [pmid: 17087666].
Bateman DN, Bain M, Gorman D, Murphy D. Changes in paracetamol, antidepressants and opioid poisoning in Scotland during the 1990s. QJM. Feb. 2003;96(2):125-32. [pmid: 12589010].
Beautrais AL. Subsequent mortality in medically serious suicide attempts: a 5 year follow-up. Aust N Z J Psychiatry. Oct. 2003;37(5):595-9. [pmid: 14511088].
Bodner E, Ben-Artzi E, Kaplan Z. Soldiers who kill themselves: the contribution of dispositional and situational factors. Arch Suicide Res. 2006;10(1):29-43. [pmid: 16287694].
Brent DA, Mann JJ. Family genetic studies, suicide, and suicidal behavior. Am J Med Genet C Semin Med Genet. Feb 15. 2005;133(1):13-24. [pmid: 15648081].
Bridges FS, Kunselman JC. Gun availability and use of guns for suicide, homicide, and murder in Canada. Percept Mot Skills. Apr. 2004;98(2):594-8. [pmid: 15141925].
Burgess P, Pirkis J, Jolley D, Whiteford H, Saxena S. Do nations’ mental health policies, programs and legislation influence their suicide rates? An ecological study of 100 countries. Aust N Z J Psychiatry. 2004 Nov-2004 Dec 31;38(11–12):933-9. [pmid: 15555028].
Carrington P. Gender, gun control, suicide, and homicide in Canada. Archives of Suicide Research. 1999;5:71-75.
Chan TY. Improvements in the packaging of drugs and chemicals may reduce the likelihood of severe intentional poisonings in adults. Hum Exp Toxicol. Jul. 2000;19(7):387-91. [pmid: 11002388].
Copley GB. Epidemiologica risk factors for suicide and attempted suicide in the U.S. Air Force: using administrative data systems and multiple case of death information to improve prevention policy. Diss Abst Int B Sci Eng. 2001:62807.
Crane C, Hawton K, Simkin S, Coulter P. Suicide and the media: pitfalls and prevention. Report on a meeting organized by the Reuters Foundation Program at Green College and University of Oxford Centre for Suicide Research at Green College, Oxford, UK, November 18, 2003. Crisis. 2005;26(1):42-7. [pmid: 15762086].
Crome P. The toxicity of drugs used for suicide. Acta Psychiatr Scand Suppl. 1993;371:33-7. [pmid: 8517181].
Dargan P, Jones A. Effects of legislation restricting pack sizes of paracetamol on self poisoning. It’s too early to tell yet. BMJ. Sep 15. 2001;323:7313-633.
Deutsch S, Alt F. The effect of Massachusetts’ gun control law on gun-related crimes in the city of Boston. Evaluation Quarterly. 1977;1:543-568.
Eaton KM, Messer SC, Garvey Wilson AL, Hoge CW. Strengthening the validity of population-based suicide rate comparisons: an illustration using U.S. military and civilian data. Suicide Life Threat Behav. 2006;36(2):182-91. [pmid: 16704323].
Feightner J and Canadian Task Force on the Periodic Health Examination. Canadian Guide to Clinical Preventitive Health Care. Ottawa, Ontario. Health Canada. 1994.
Florkowski A, Gruszczynski W, Wawrzyniak Z. Evaluation of psychopathological factors and origins of suicides committed by soldiers, 1989 to 1998. Mil Med. Jan. 2001;166(1):44-7. [pmid: 11197097].
Gibbons RD, Hur K, Bhaumik DK, Mann JJ. The relationship between antidepressant medication use and rate of suicide. Arch Gen Psychiatry. Feb. 2005;62(2):165-72. [pmid: 15699293].
Gilbody S, Whitty P, Grimshaw J, Thomas R. Educational and organizational interventions to improve the management of depression in primary care: a systematic review. JAMA. Jun 18. 2003;289(23):3145-51. [pmid: 12813120].
Giles-Sims J, Lockhart C. Explaining cross-state differences in elderly suicide rates and identifying state-level public policy responses that reduce rates. Suicide Life Threat Behav. 2006;36(6):694-708. [pmid: 17250474].
Goldney RD, Fisher LJ, Wilson DH. Mental health literacy: an impediment to the optimum treatment of major depression in the community. J Affect Disord. May. 2001;64(2–3):277-84. [pmid: 11313096].
Greer S, Bagley C. Effect of psychiatric intervention in attempted suicide: a controlled study. Br Med J. Feb 6. 1971;1(5744):310-2. [pmid: 5100261].
Grossman DC, Mueller BA, Riedy C, Dowd MD, Villaveces A, Prodzinski J, Nakagawara J, Howard J, Thiersch N, Harruff R. Gun storage practices and risk of youth suicide and unintentional firearm injuries. JAMA. Feb 9. 2005;293(6):707-14. [pmid: 15701912].
Gunnell D, Middleton N, Frankel S. Method availability and the prevention of suicide--a re-analysis of secular trends in England and Wales 1950–1975. Soc Psychiatry Psychiatr Epidemiol. Oct. 2000;35(10):437-43. [pmid: 11127717].
Hannaford PC, Thompson C, Simpson M. Evaluation of an educational programme to improve the recognition of psychological illness by general practitioners. Br J Gen Pract. Jun. 1996;46(407):333-7. [pmid: 8983250].
Hartl TL, Rosen C, Drescher K, Lee TT, Gusman F. Predicting high-risk behaviors in veterans with posttraumatic stress disorder. J Nerv Ment Dis. 2005;193(7):464-72. [pmid: 15985841].
Hawton K, Simkin S, Deeks J. Co-proxamol and suicide: a study of national mortality statistics and local non-fatal self poisonings. BMJ. May 10. 2003;326(7397):1006-8. [pmid: 12742920].
Hegerl U, Althaus D, Stefanek J. Public attitudes towards treatment of depression: effects of an information campaign. Pharmacopsychiatry. Nov. 2003;36(6):288-91. [pmid: 14663652].
Henkel V, Mergl R, Kohnen R, Maier W, Moller HJ, Hegerl U. Identifying depression in primary care: a comparison of different methods in a prospective cohort study. BMJ. Jan 25. 2003;326(7382):200-1. [pmid: 12543837].
Hirschfeld RM, Keller MB, Panico S, Arons BS, Barlow D, Davidoff F, Endicott J, Froom J, Goldstein M, Gorman JM, Marek RG, Maurer TA, Meyer R, Phillips K, Ross J, Schwenk TL, Sharfstein SS, Thase ME, Wyatt RJ. The National Depressive and Manic-Depressive Association consensus statement on the undertreatment of depression. JAMA. 1997 Jan 22-1997 Jan 29;277(4):333-40.
Isbister G, Balit C. Effects of legislation restricting pack sizes of paracetamol on self poisoning. Authors did not look at effects on all deliberate and accidental self poisoning. BMJ. Sep 15. 2001;323(7313):633-4. [pmid: 11575320].
Jorm AF, Christensen H, Griffiths KM. The impact of beyondblue: the national depression initiative on the Australian public’s recognition of depression and beliefs about treatments. Aust N Z J Psychiatry. Apr. 2005;39(4):248-54. [pmid: 15777361].
Kaleveld L, English B. Evaluating a suicide prevention program: a question of impact. Health Promot J Austr. Aug. 2005;16(2):129-33. [pmid: 16130588].
Kapur S, Mieczkowski T, Mann JJ. Antidepressant medications and the relative risk of suicide attempt and suicide. JAMA. 1992 Dec 23–1992 Dec 30;268(24):3441-5.
Kelly C. The effects of depression awareness seminars on general practitioners knowledge of depressive illness. Ulster Med J. May. 1998;67(1):33-5. [pmid: 9652197].
Kelly S, Bunting J. Trends in suicide in England and Wales, 1982–96. Popul Trends. Summer. 1998;92:29-41. [pmid: 9679269].
Kennedy P. Efficacy of a regional poisoning treatment centre in preventing further suicidal behaviour. Br Med J. Nov 4. 1972;4(5835):255-7. [pmid: 5083883].
Laing W, Gordon L, Lee D, Good A, Bateman D. Have the new pack size regulations impacted on UK paracetamol overdose?. J Toxicol Clin Toxicol. 2001;39:301.
Lester D. Firearm availability and use of firearms for suicide and homicide. Perceptual and Motor Skills. 2000;91:758. [pmid: 11153844].
Lin EH, Simon GE, Katzelnick DJ, Pearson SD. Does physician education on depression management improve treatment in primary care?. J Gen Intern Med. Sep. 2001;16(9):614-9. [pmid: 11556942].
Luoma JB, Martin CE, Pearson JL. Contact with mental health and primary care providers before suicide: a review of the evidence. Am J Psychiatry. Jun. 2002;159(6):909-16. [pmid: 12042175].
Mahon MJ, Tobin JP, Cusack DA, Kelleher C, Malone KM. Suicide among regular-duty military personnel: a retrospective case-control study of occupation-specific risk factors for workplace suicide. Am J Psychiatry. 2005;162(9):1688-96. [pmid: 16135629].
Marzuk PM, Leon AC, Tardiff K, Morgan EB, Stajic M, Mann JJ. The effect of access to lethal methods of injury on suicide rates. Arch Gen Psychiatry. Jun. 1992;49(6):451-8. [pmid: 1599369].
McClure GM. Changes in suicide in England and Wales, 1960–1997. Br J Psychiatry. Jan. 2000;176:64-7. [pmid: 10789329].
McLeavey BC, Daly RJ, Ludgate JW, Murray CM. Interpersonal problem-solving skills training in the treatment of self-poisoning patients. Suicide Life Threat Behav. Winter. 1994;24(4):382-94. [pmid: 7740595].
Miller M, Hemenway D, Azrael D. Firearms and suicide in the northeast. J Trauma. Sep. 2004;57(3):626-32. [pmid: 15454813].
Mills PD, Neily J, Luan D, Osborne A, Howard K. Actions and implementation strategies to reduce suicidal events in the Veterans Health Administration. Jt Comm J Qual Patient Saf. 2006;32(3):130-41. [pmid: 16617944].
Ministry of Health. Suicide and the Media: The Reporting and Portrayal of suicide in the Media. Wellington. Ministry of Health. 1999.
Mundt RJ. Gun control and rates of firearms violence in Canada and the United States. Canadian Journal of Criminology. 1990;32:137-154.
Naismith SL, Hickie IB, Scott EM, Davenport TA. Effects of mental health training and clinical audit on general practitioners’ management of common mental disorders. Med J Aust. Jul 16. 2001;175(Suppl):S42-7. [pmid: 11556436].
Paykel ES, Hart D, Priest RG. Changes in public attitudes to depression during the Defeat Depression Campaign. Br J Psychiatry. Dec. 1998;173:519-22. [pmid: 9926082].
Pettit JW, Paukert AL, Joiner TE Jr, Rudd MD. Pilot sample of very early onset bipolar disorder in a military population moderates the association of negative life events and non-fatal suicide attempt. Bipolar Disord. 2006;8(5 Pt 1):475-84. [pmid: 17042885].
Pfaff JJ, Acres JG, McKelvey RS. Training general practitioners to recognise and respond to psychological distress and suicidal ideation in young people. Med J Aust. Mar 5. 2001;174(5):222-6. [pmid: 11280692].
Platt S, McLean J, McCollam A, Blamey A, Mackenzie M, McDaid D, Maxwell M, Halliday E, Woodhouse A. Evaluation of the first phase of Choose Life: the National Strategy and Action Plan to Prevent Suicide in Scotland 2006. Edinburgh. Scottish Executive Social Research.
Rabasca L. Military suicide-prevention program reduces the stigma of seeking help. Am Psychol Assoc Monitor. 1999;30(9):8.
Rihmer Z, Belso N, Kalmar S. Antidepressants and suicide prevention in Hungary. Acta Psychiatr Scand. Mar. 2001;103(3):238-9. [pmid: 11240584].
Sakinofsky I. The current evidence base for the clinical care of suicidal patients: strengths and weaknesses. Can J Psychiatry. 2007;52(6 Suppl 1):7S-20S. [pmid: 17824349].
Sakinofsky I. Treating suicidality in depressive illness. Part 2: does treatment cure or cause suicidality?. Can J Psychiatry. 2007;52(6 Suppl 1):85S-101S. [pmid: 17824355].
Saunders K, Hawton K. Suicide prevention and audit. Br J Hosp Med (Lond). 2005;66(11):627-30. [pmid: 16308949].
Scarff E. Evaluation of the Canadian gun control legislation: final report. Ottawa. Canadian Government Publishing Centre. 1983.
Scoville SL, Gubata ME, Potter RN, White MJ, Pearse LA. Deaths attributed to suicide among enlisted U.S. Armed Forces recruits, 1980–2004. Mil Med. 2007;172(10):1024-31. [pmid: 17985760].
Sheen C, Dillon J. The effect on toxicity and healthcare costs on reducing the size of available acetaminophen pack sizes in the Tayside region of Scotland. Gastroenterology. 2001;120(Suppl 1):A-228.
Sheen CL, Dillon JF, Bateman DN, Simpson K, MacDonald TM. The effect on toxicity on reducing the size of available paracetamol pack sizes. Gut. 2001;48(Suppl 1):A105.
Sheen CL, Dillon JF, Bateman DN, Simpson KJ, MacDonald TM. Paracetamol pack size restriction: the impact on paracetamol poisoning and the over-the-counter supply of paracetamol, aspirin and ibuprofen. Pharmacoepidemiol Drug Saf. Jun. 2002;11(4):329-31. [pmid: 12138601].
Shenassa ED, Rogers ML, Spalding KL, Roberts MB. Safer storage of firearms at home and risk of suicide: a study of protective factors in a nationally representative sample. J Epidemiol Community Health. Oct. 2004;58(10):841-8. [pmid: 15365110].
Sloan JH, Rivara FP, Reay DT, Ferris JA, Kellermann AL. Firearm regulations and rates of suicide. A comparison of two metropolitan areas. N Engl J Med. Feb 8. 1990;322(6):369-73. [pmid: 2393410].
Sorenson SB, Vittes KA. Mental health and firearms in community-based surveys: implications for suicide prevention. Eval Rev. 2008;32(3):239-56. [pmid: 18456876].
Stuart H. Fighting stigma and discrimination is fighting for mental health. Canadian Public Policy. 2005:S21-S28.
Thoresen S, Mehlum L. Suicide in peacekeepers: risk factors for suicide versus accidental death. Suicide Life Threat Behav. 2006;36(4):432-42. [pmid: 16978097].
Thoresen S, Mehlum L, Roysamb E, Tonnessen A. Risk factors for completed suicide in veterans of peacekeeping: repatriation, negative life events, and marital status. Arch Suicide Res. 2006;10(4):353-63. [pmid: 16920686].
Tiet QQ, Finney JW, Moos RH. Recent sexual abuse, physical abuse, and suicide attempts among male veterans seeking psychiatric treatment. Psychiatr Serv. 2006;57(1):107-13. [pmid: 16399970].
Tiet QQ, Ilgen MA, Byrnes HF, Moos RH. Suicide attempts among substance use disorder patients: an initial step toward a decision tree for suicide management. Alcohol Clin Exp Res. 2006;30(6):998-1005. [pmid: 16737458].
Troister T, Links PS, Cutcliffe J. Review of predictors of suicide within 1 year of discharge from a psychiatric hospital. Curr Psychiatry Rep. 2008;10(1):60-5. [pmid: 18269896].
Unutzer J, Katon W, Callahan CM, Williams JW Jr, Hunkeler E, Harpole L, Hoffing M, Della Penna RD, Noel PH, Lin EH, Arean PA, Hegel MT, Tang L, Belin TR, Oishi S, Langston C. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. Dec 11. 2002;288(22):2836-45. [pmid: 12472325].
Valentini W, Levav I, Kohn R, Miranda CT, Mello AA, Mello MF, Ramos CP. [An educational training program for physicians for diagnosis and treatment of depression]. Rev Saude Publica. Aug. 2004;38(4):522-8. [pmid: 15311292].
Voaklander DC, Rowe BH, Dryden DM, Pahal J, Saar P, Kelly KD. Medical illness, medication use and suicide in seniors: a population-based case-control study. Epidemiol Community Health. 2008;62(2):138-46.
Vuorilehto MS, Melartin TK, Isometsa ET. Suicidal behaviour among primary-care patients with depressive disorders. Psychol Med. 2006;36(2):203-10. [pmid: 16420714].
Zivin K, Kim HM, McCarthy JF, Austin KL, Hoggatt KJ, Walters H, Valenstein M. Suicide mortality among individuals receiving treatment for depression in the Veterans Affairs health system: associations with patient and treatment setting characteristics. Am J Public Health. 2007;97(12):2193-8. [pmid: 17971541].

### Adolescent

Rotheram-Borus MJ, Piacentini J, Cantwell C, Belin TR, Song J. The 18-month impact of an emergency room intervention for adolescent female suicide attempters. J Consult Clin Psychol. Dec. 2000;68(6):1081-93. [pmid: 11142542].

### Design- Other

Appleby L, Sherratt J. Good clinical practice on suicide and suicide prevention. Psychiatr Bull R Coll Psychiatr. 2001:2541-42.

## EXCLUDED AT FURTHER REVIEW (N=49)

### Country

Apter A, King RA, Bleich A, Fluck A, Kotler M, Kron S. Fatal and non-fatal suicidal behavior in Israeli adolescent males. Arch Suicide Res. 2008;12(1):20-9. [pmid: 18240031].
Bellanger MM, Jourdain A, Batt-Moillo A. Might the decrease in the suicide rates in France be due to regional prevention programmes?. Soc Sci Med. 2007;65(3):431-41. [pmid: 17475385].
Bradvik L, Berglund M. Long-term treatment and suicidal behavior in severe depression: ECT and antidepressant pharmacotherapy may have different effects on the occurrence and seriousness of suicide attempts. Depress Anxiety. 2006;23(1):34-41. [pmid: 16315268].
Cedereke M, Monti K, Ojehagen A. Telephone contact with patients in the year after a suicide attempt: does it affect treatment attendance and outcome? A randomised controlled study. Eur Psychiatry. Apr. 2002;17(2):82-91. [pmid: 11973116].
De Leo D, Dello Buono M, Dwyer J. Suicide among the elderly: the long-term impact of a telephone support and assessment intervention in northern Italy. Br J Psychiatry. Sep. 2002;181:226-9. [pmid: 12204927].
Dieserud G, Loeb M, Ekeberg O. Suicidal behavior in the municipality of Baerum, Nor-way: a 12-year prospective study of parasuicide and suicide. Suicide Life Threat Behav. Spring. 2000;30(1):61-73. [pmid: 10782719].
Gunnell D, Fernando R, Hewagama M, Priyangika WD, Konradsen F, Eddleston M. The impact of pesticide regulations on suicide in Sri Lanka. Int J Epidemiol. 2007.
Hegerl U, Althaus D, Schmidtke A, Niklewski G. The alliance against depression: 2-year evaluation of a community-based intervention to reduce suicidality. Psychol Med. Sep. 2006;36(9):1225-33. [pmid: 16707028].
Kapusta ND, Etzersdorfer E, Krall C, Sonneck G. Firearm legislation reform in the European Union: impact on firearm availability, firearm suicide and homicide rates in Austria. Br J Psychiatry. 2007;191:253-7. [pmid: 17766767].
Matakas F, Rohrbach E. Suicide prevention in the psychiatric hospital. Suicide Life Threat Behav. 2007;37(5):507-17. [pmid: 17967117].
Ohberg A, Lonnqvist J, Sarna S, Vuori E, Penttila A. Trends and availability of suicide methods in Finland. Proposals for restrictive measures. Br J Psychiatry. Jan. 1995;166(1):35-43. [pmid: 7894873].
Oyama H, Fujita M, Goto M, Shibuya H, Sakashita T. Outcomes of community-based screening for depression and suicide prevention among Japanese elders. Gerontologist. Dec. 2006;46(6):821-6. [pmid: 17169937].
Oyama H, Goto M, Fujita M, Shibuya H, Sakashita T. Preventing elderly suicide through primary care by community-based screening for depression in rural Japan. Crisis. 2006;27(2):58-65. [pmid: 16913326].
Oyama H, Koida J, Sakashita T, Kudo K. Community-based prevention for suicide in elderly by depression screening and follow-up. Community Ment Health J. Jun. 2004;40(3):249-63. [pmid: 15259630].
Oyama H, Ono Y, Watanabe N, Tanaka E, Kudoh S, Sakashita T, Sakamoto S, Neichi K, Satoh K, Nakamura K, Yoshimura K. Local community intervention through depression screening and group activity for elderly suicide prevention. Psychiatry Clin Neurosci. 2006;60(1):110-4. [pmid: 16472368].
Oyama H, Watanabe N, Ono Y, Sakashita T, Takenoshita Y, Taguchi M, Takizawa T, Miura R, Kumagai K. Community-based suicide prevention through group activity for the elderly successfully reduced the high suicide rate for females. Psychiatry Clin Neurosci. 2005;59(3):337-44. [pmid: 15896228].
Raj MAJ, Kumaraiah V, Bhide AV. Cognitive-behavioural intervention in deliberate self-harm. Acta Psychiatr Scand. 2001;104:340-5. [pmid: 11722314].
Rutz W, von Knorring L, Walinder J. Frequency of suicide on Gotland after systematic postgraduate education of general practitioners. Acta Psychiatr Scand. Aug. 1989;80(2):151-4. [pmid: 2801163].
Szanto K, Kalmar S, Hendin H, Rihmer Z, Mann JJ. A suicide prevention program in a region with a very high suicide rate. Arch Gen Psychiatry. 2007;64(8):914-20. [pmid: 17679636].
Torhorst A, Moller HJ, Burk F, Kurz A, Wachtler C, Lauter H. The psychiatric management of parasuicide patients: a controlled clinical study comparing different strategies of outpatient treatment. Crisis. Mar. 1987;8(1):53-61. [pmid: 3595176].
Torhorst A, Moller HJ, Schimid-Bode KW. Comparing a 3-month and a 12-month out-patient aftercare program for parasuicide repeaters. Current Issues of Suicidology. Berlin, Germany. Springer-Verlag. 1988:19-24.
Vaiva G, Vaiva G, Ducrocq F, Meyer P, Mathieu D, Philippe A, Libersa C, Gou-demand M. Effect of telephone contact on further suicide attempts in patients discharged from an emergency department: randomised controlled study. Bmj. 2006;332(7552):1241-5. [pmid: 16735333].
van den Bosch LM, Koeter MW, Stijnen T, Verheul R, van den Brink W. Sustained efficacy of dialectical behaviour therapy for borderline personality disorder. Behav Res Ther. 2005;43(9):1231-41. [pmid: 16005708].
van der Sande R, van Rooijen L, Buskens E, Allart E, Hawton K, van der Graaf Y, van Engeland H. Intensive in-patient and community intervention versus routine care after attempted suicide. A randomised controlled intervention study. Br J Psychiatry. Jul. 1997;171:35-41. [pmid: 9328492].
Van Heeringen C, Jannes S, Buylaert W, Henderick H, De Bacquer D, Van Remoor-tel J. The management of non-compliance with referral to out-patient after-care among attempted suicide patients: a controlled intervention study. Psychol Med. Sep. 1995;25(5):963-70. [pmid: 8588015].
Varnik A, Kolves K, Vali M, Tooding LM, Wasserman D. Do alcohol restrictions reduce suicide mortality?. Addiction. 2007;102(2):251-6. [pmid: 17222279].
Verkes RJ, Van der Mast RC, Hengeveld MW, Tuyl JP, Zwinderman AH, Van Kempen GM. Reduction by paroxetine of suicidal behavior in patients with repeated suicide attempts but not major depression. Am J Psychiatry. Apr. 1998;155(4):543-7. [pmid: 9546002].
Zonda T, Lester D. Preventing suicide by educating general practitioners. Omega (West-port). 2006;54(1):53-7.

### Pharmacotherapy

Battaglia J, Wolff TK, Wagner-Johnson DS, Rush AJ, Carmody TJ, Basco MR. Structured diagnostic assessment and depot fluphenazine treatment of multiple suicide attempters in the emergency department. Int Clin Psychopharmacol. Nov. 1999;14(6):361-72. [pmid: 10565804].
Coryell W, Arndt S, Turvey C, Endicott J, Solomon D, Mueller T, Leon AC, Keller M. Lithium and suicidal behavior in major affective disorder: a case-control study. Acta Psychiatr Scand. Sep. 2001;104(3):193-7. [pmid: 11531655].
Ludwig J, Marcotte DE, Norberg K. Anti-Depressants and Suicide. 2007. Feb.
Montgomery DB, Roberts A, Green M, Bullock T, Baldwin D, Montgomery SA. Lack of efficacy of fluoxetine in recurrent brief depression and suicidal attempts. Eur Arch Psychiatry Clin Neurosci. 1994;244(4):211-5. [pmid: 7888419].
Montgomery S, Cronholm B, Asberg M, Montgomery DB. Differential effects on suicidal ideation of mianserin, maprotiline and amitriptyline. Br J Clin Pharmacol. 1978;5(Suppl 1):77S-80S. [pmid: 341948].
Montgomery SA, Roy D, Montgomery DB. The prevention of recurrent suicidal acts. Br J Clin Pharmacol. 1983;15(Suppl 2):183S-188S. [pmid: 6824553].
Verkes RJ, Van der Mast RC, Hengeveld MW, Tuyl JP, Zwinderman AH, Van Kempen GM. Reduction by paroxetine of suicidal behavior in patients with repeated suicide attempts but not major depression. Am J Psychiatry. Apr. 1998;155(4):543-7. [pmid: 9546002].

### Psychotherapy

Bateman A, Fonagy P. Effectiveness of partial hospitalization in the treatment of borderline personality disorder: a randomized controlled trial. Am J Psychiatry. Oct. 1999;156(10):1563-9. [pmid: 10518167].
Blum N, St John D, Pfohl B, Stuart S, McCormick B, Allen J, Arndt S, Black DW. Systems Training for Emotional Predictability and Problem Solving (STEPPS) for outpatients with borderline personality disorder: a randomized controlled trial and 1-year follow-up. Am J Psychiatry. 2008;165(4):468-78. [pmid: 18281407].
Bradvik L, Berglund M. Long-term treatment and suicidal behavior in severe depression: ECT and antidepressant pharmacotherapy may have different effects on the occurrence and seriousness of suicide attempts. Depress Anxiety. 2006;23(1):34-41. [pmid: 16315268].
Evans K, Tyrer P, Catalan J, Schmidt U, Davidson K, Dent J, Tata P, Thornton S, Barber J, Thompson S. Manual-assisted cognitive-behaviour therapy (MACT): a randomized controlled trial of a brief intervention with bibliotherapy in the treatment of recurrent deliberate self-harm. Psychol Med. Jan. 1999;29(1):19-25. [pmid: 10077290].
Liberman RP, Eckman T. Behavior therapy vs insight-oriented therapy for repeated suicide attempters. Arch Gen Psychiatry. Oct. 1981;38(10):1126-30. [pmid: 7027988].
Linehan MM, Armstrong HE, Suarez A, Allmon D, Heard HL. Cognitive-behavioral treatment of chronically parasuicidal borderline patients. Arch Gen Psychiatry. Dec. 1991;48(12):1060-4. [pmid: 1845222].
Linehan MM, Comtois KA, Murray AM, Brown MZ, Gallop RJ, Heard HL, Korslund KE, Tutek DA, Reynolds SK, Lindenboim N. Two-year randomized controlled trial and follow-up of dialectical behavior therapy vs therapy by experts for suicidal behaviors and borderline personality disorder. Arch Gen Psychiatry. 2006;63(7):757-66. [pmid: 16818865].
Matakas F, Rohrbach E. Suicide prevention in the psychiatric hospital. Suicide Life Threat Behav. 2007;37(5):507-17. [pmid: 17967117].
Patsiokas AT, Clum GA. Effects of psychotherapeutic strategies in the treatment of suicide attempters. Journal of Psychotherapy. 1985;22(281).
Raj MAJ, Kumaraiah V, Bhide AV. Cognitive-behavioural intervention in deliberate self-harm. Acta Psychiatr Scand. 2001;104:340-5. [pmid: 11722314].
Rudd MD, Rajab MH, Orman DT, Joiner T, Stulman DA, Dixon W. Effectiveness of an outpatient intervention targeting suicidal young adults: preliminary results. J Consult Clin Psychol. Feb. 1996;64(1):179-90. [pmid: 8907098].
Salkovskis PM, Atha C, Storer D. Cognitive-behavioural problem solving in the treatment of patients who repeatedly attempt suicide. A controlled trial. Br J Psychiatry. Dec. 1990;157:871-6. [pmid: 2289097].
Tarrier N, Haddock G, Lewis S, Drake R, Gregg L. Suicide behaviour over 18 months in recent onset schizophrenic patients: the effects of CBT. Schizophr Res. 2006;83(1):15-27. [pmid: 16460916].
Torhorst A, Moller HJ, Burk F, Kurz A, Wachtler C, Lauter H. The psychiatric management of parasuicide patients: a controlled clinical study comparing different strategies of outpatient treatment. Crisis. Mar. 1987;8(1):53-61. [pmid: 3595176].
Tyrer P, Thompson S, Schmidt U, Jones V, Knapp M, Davidson K, Catalan J, Airlie J, Baxter S, Byford S, Byrne G, Cameron S, Caplan R, Cooper S, Ferguson B, Freeman C, Frost S, Godley J, Greenshields J, Henderson J, Holden N, Keech P, Kim L, Logan K, Manley C, MacLeod A, Murphy R, Patience L, Ramsay L, De Munroz S, Scott J, Seivewright H, Sivakumar K, Tata P, Thornton S, Ukoumunne OC, Wessely S. Randomized controlled trial of brief cognitive behaviour therapy versus treatment as usual in recurrent deliberate self-harm: the POPMACT study. Psychol Med. Aug. 2003;33(6):969-76. [pmid: 12946081].
van den Bosch LM, Koeter MW, Stijnen T, Verheul R, van den Brink W. Sustained efficacy of dialectical behaviour therapy for borderline personality disorder. Behav Res Ther. 2005;43(9):1231-41. [pmid: 16005708].
Weinberg I, Gunderson JG, Hennen J, Cutter CJ Jr. Manual assisted cognitive treatment for deliberate self-harm in borderline personality disorder patients. J Personal Disord. 2006;20(5):482-92.

### Suicidal Ideation

Bruce ML, Ten Have TR, Reynolds CF 3rd, Katz II, Schulberg HC, Mulsant BH, Brown GK, McAvay GJ, Pearson JL, Alexopoulos GS. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. Mar 3. 2004;291(9):1081-91. [pmid: 14996777].
Montgomery S, Cronholm B, Asberg M, Montgomery DB. Differential effects on suicidal ideation of mianserin, maprotiline and amitriptyline. Br J Clin Pharmacol. 1978;5(Suppl 1):77S-80S. [pmid: 341948].
Patsiokas AT, Clum GA. Effects of psychotherapeutic strategies in the treatment of suicide attempters. Journal of Psychotherapy. 1985;22:281.
Raj MAJ, Kumaraiah V, Bhide AV. Cognitive-behavioural intervention in deliberate self-harm. Acta Psychiatr Scand. 2001;104:340-5. [pmid: 11722314].