# DATA COLLECTION FORMS

VA ESP - Suicide Prevention Pre Screener

VA-ESP Suicide Prevention Detail Intervention & Quality Review Form