# RESULTS

## LITERATURE SEARCH AND STUDY CHARACTERISTICS

The combined literature search of PubMed, Embase, PsycINFO, and Cochrane databases, minus duplicates, contained 884 unique citations, of which we excluded 792 after reviewing titles and abstracts. We then conducted full-text reviews of 92 articles and pulled 6 additional papers in order to retrieve supplemental methodological or background information on studies included in the full-text review. Of these 98 papers, we excluded 75. Figure 2 summarizes the literature flow. The 23 included reports encompassed 16 unique trials with a total of 3,553 depressed and nondepressed participants. Table 3 summarizes study characteristics. In studies that included depressed and nondepressed participants, we report information for the depressed subgroup when available.

Figure 2 Literature Flow Diagram

Table 3 Summary of Study Characteristics

Study, year | Study quality^a^ | Sample size | Age Mean (SD) | % Female | % white | FTND Mean (SD) | Cigarettes per day Mean (SD) | Depressed mood at baseline Mean (SD)
Brown, 2001 | Good | 179 All MDD history positive | 45.1 (9.3) | 59.8 | 97.2 | 6.8 (1.9) | NR | BDI: 7.8 (6.31)
Covey, 1999 | Fair | 80 45% MDD history positive | 33.8^b^ (8.2) | 68.0^b^ | NR | NR | 30.3 (10.1) | NR
Covey, 2002 | Good | 134 All MDD history positive | 44.5 (10.7) | 63.4 | 87.3 | 6.1(2.4)^b^ | NR | BDI: 8.0 (7.7) CES-D: 14.9 (10.8) HDRS: 4.8 (4.4)
Duffy, 2006 | Good | 184 35% depressed smokers | 57.0 (9.9) | 16.0 | 90.0 | NR | NR | NR
Evins, 2008 | Good | 199 All MDD history positive | 43.0 (11.0) | 49.0 | NR | 5.8 (2.2) | 25.0 (11) | HDRS: 10.6 (6.3)
Hall, 1994 | Fair | 149 31% MDD history positive | 40.6 (9.2) | 52.0 | 88.0 | 6.4 (1.9) | 24.9 (10.9) | BDI: 6.4 (5.9)^c^
Hall, 1996 | Fair | 201 22% MDD history positive | 39.7 (NR) | 52.0 | 92.0 | NR | 23.8 (9.8) | BDI: 6.7 (5.4)
Hall, 1998 | Good | 199 33% MDD history positive | 41.9^c^ (9.9) | 42.0^c^ | 59.0^c^ | 5.5 (2.2)^c^ | 21.8 (10.4)^c^ | BDI: 12.1 (8.3)^c^
Hall, 2006 | Good | 322 All with current depression | 41.5^b^ (12.4) | 69.6 | 68.3 | 3.8 (2.4) | 15.8 (10.0) | BDI: 20.6 (11.7)^b^
Hayford, 1999 | Good | 615 19% MDD history positive | 42.2 – 43.7^d^ | 54.6 | 96 | FTQ: 7.1–7.3 (1.7)^d^ | 26.2(8.5) –27.5(9.6)^d^ | BDI: 4.1(4.2) – 4.7 (5.0)^d^
Kinnunen, 1996 | Good | 269 34% met criteria for depression | 40.4 (12.6)^c^ 41.6 (12.7) | 51.0 61.0^c^ | 82.0 80.0^c^ | 5.6 (2.4)^c^ | 22 (10.4)^c^ | NR
Kinnunen, 2008 | Good | 608 32% met criteria for depression | 38.5 (11.3)^c^ | 51.0^c^ | 78.6^c^ | Women: 5.6(2.3)^c^ Men: 6.2 (2.3)^c^ | Women: 21.0(10.0)^c^ men:26.6(11.7)^c^ | CES-D: Women: 24.8(7.0)^c^ Men: 24.4 (6.9)^c^
MacPherson, 2010 | Good | 68 All with mildly elevated depressive symptoms | 45.0 (12.2)^b^ | 48.5 (NR) | 27.3 | 5.8 (1.8)^b^ | 18.8 (7.1)^b^ | BDI: 10.8 (5.2)^b^
Munoz, 1997 | Fair | 136 78% MDE history positive | 35.3 (NR) | 38.2 | 0.0 | NR | 14.1 (8.2) | CES-D: 21.3 (13.9)
Saules, 2004 | Fair | 150 20% MDD history positive | 39.8 (NR) | 54.5 | 73.2 | 5.9 (NR) | NR | BDI: 4.92 (NR)
Vickers, 2009 | Fair | 60 All with current depression | 41.8 (12.1)^b^ | 100.0 | 98.0^b^ | NR | 21.6 (11.1)^b^ | HRSD: 12.8 (6.0) CES-D: 29.8 (9.3)

a Study quality assessed via key quality criteria described in AHRQ’s General Methods Guide.

b Mean for intervention arm only.

c Mean for depressed subgroup.

d Range of means from randomized groups at baseline.

Abbreviations: BDI = Beck Depression Inventory, CES-D = Center for Epidemiologic Studies-Depression Scale, FTQ = Fagerstrom Tolerance Questionnaire, FTND = Fagerstrom Test for Nicotine Dependence, HDRS = Hamilton Depression Rating Scale, NR = not reported, MDD = major depressive disorder; MDE = major depressive episode

Most studies were of good quality according to quality criteria described in AHRQ’s General Methods Guide.42 All studies were conducted in the U.S. with English-speaking participants except one, which was conducted with Spanish speakers living in the U.S.51 All reports, except one,52 reported smoking cessation outcomes for at least 6 months from the start of the trial. Most studies excluded participants with current MDD; however, 19 to 78% of participants in these studies had a history of MDD or exceeded a screening threshold for significant depressive symptoms. Of the studies that recruited smokers with depression, three recruited MDD history-positive participants,53–55 two recruited participants with current depression as measured by the CES-D56 or the PRIME-MD,57 and one recruited participants with mildly elevated depressive symptoms as assessed by the BDI-II.58 For the remainder of this report, we refer to depression as (1) significant depressive symptoms as measured by validated assessment instrument (e.g., CES-D, BDI) or (2) a history of MDD.

## KEY QUESTION 1 For patients with a history of a depressive disorder or current significant depressive symptoms, what is the comparative effectiveness of different smoking cessation strategies on smoking abstinence rates?

### Intervention Types

All but two interventions tested combination therapies consisting of some type of counseling and pharmacotherapy.51,53 Of the studies that included behavioral counseling, the most common therapy was CBT conducted in person via small group or individual therapy. Only one included study conducted behavioral counseling via telephone.59 Six studies included a behavioral mood management treatment.44,45,53,58–60 Mood management treatments ranged from smoking cessation–focused behavioral counseling augmented with one-time additional mood management counseling to intensive multisession group or individual CBT counseling. One study included mood management content delivered via mailed print materials.51 Of the studies that included antidepressant pharmacotherapies, four used bupropion,55,57,59,61 and three tested some other antidepressant (i.e., sertraline, fluoxetine, nortriptyline).45,54,62 Of studies that included antidepressants, two used NRT as a cotreatment,55,62 and two used NRT as a first-line therapy before offering bupropion.57,59 One study tested behavioral counseling plus a pill formulation of a long-acting opiate antagonist, naltrexone, as a smoking cessation aid.63 No studies using varenicline were identified that met our eligibility criteria. Below, we summarize the evidence for smoking cessation interventions for adults with depression. When able, we conducted meta-analysis to quantitatively summarize evidence of comparative effectiveness of interventions.

### Comparative Effectiveness of Smoking Cessation Strategies

[underlined: NRT + Brief counseling versus placebo + brief counseling.] Two studies of good quality compared the addition of nicotine gum to brief counseling compared to brief counseling plus placebo (Table 4).52,64 Kinnunen and colleagues (1996) compared the addition of 2 or 4 mg of nicotine gum to one-time brief counseling. Participants were advised to use the gum ad lib, with a target range of 9 to 15 pieces a day. In a subgroup analysis of participants with significant depressive symptoms as measured via the CES-D (n= 93), smokers with depression receiving either active gum dose were more likely to quit smoking than smokers with depression receiving placebo gum (29.5% versus 12.5%; p-value NR) at 3 months post–quit date. In another trial, Kinnunen and colleagues (2008) reported the long-term effects of adding 2 or 4 mg of nicotine gum to 9 sessions of brief, 5- to 10-minute counseling sessions. Among participants with depression (n = 196), smokers receiving nicotine gum were more likely to remain abstinent at 12 month post–quit date than were smokers receiving placebo gum (15.1% versus 5.7%; p = 0.01).

Table 4 Smoking Cessation Studies of NRT Plus Brief Counseling Versus Placebo Plus Brief Counseling

Study, year | Intervention | Comparator | Follow-up duration
Kinnunen, 1996 | Nicotine gum + one-time brief individual behavioral counseling | Placebo gum + one-time brief individual behavioral counseling | 3 months
Kinnunen, 2008 | Nicotine gum + 9 brief in-person individual counseling sessions | Placebo gum + 9 brief in-person individual counseling sessions | 12 months

[underlined: NRT + Behavioral counseling versus active control.] Two studies compared the addition of NRT to behavioral counseling.44,57 In a two-by-two factorial design, Hall and colleagues (1996) compared nicotine gum to placebo gum with 10 sessions of group CBT smoking cessation counseling versus 10 sessions of health education (Table 5). Analyses were collapsed across treatment arms. Participants were given 2 mg nicotine gum or placebo gum starting at counseling session three and instructed to chew one piece per hour, 12 hours per day for the next 8 weeks. At Week 8, participants were given enough gum to taper treatment over the next 4 weeks. Smoking status was obtained and confirmed with biological assessments at Weeks 8, 12, 26, and 52. For MDD history-positive participants (n = 88), 22% receiving nicotine gum were abstinent compared to 33% receiving placebo gum at 52 weeks (p-value NR). This study was of fair quality due to omission of several key quality indicators (i.e., follow-up rates, randomization and allocation procedures, baseline characteristics).

Table 5 Smoking Cessation Studies of NRT Plus Behavioral Counseling Versus Active Control

Study, year | Intervention | Comparator | Follow-up duration
Hall, 1996 a | Nicotine gum + 10 sessions of group CBT smoking cessation counseling or 10 session health education | Placebo gum 10 sessions of group CBT smoking cessation counseling or 10 sessions health education | 12 month
Hall, 2006 | Transdermal nicotine patch (or bupropion if failed NRT) + staged motivational feedback + 6 sessions of individual CBT smoking cessation counseling | Brief contact + list of referrals to smoking cessation programs and stop smoking guide | 18 months

a Factorial design and analysis collapsed across treatment arms.

In a study of good quality, Hall and colleagues (2006) offered nicotine patches plus 6 weeks of individual staged-care CBT behavioral counseling and computerized motivational feedback (Table 5). All participants had a current diagnosis of depression based on the PRIME-MD. Counseling sessions lasted 30 minutes and took place over 8 weeks. Participants were offered 21 mg patches for the first 6 weeks, 14 mg patches for the following 2 weeks, and then offered 7 mg patches for an additional 2 weeks. If patients did not quit smoking with NRT or relapsed during treatment, patients could request bupropion. A brief contact and smoking cessation referral served as the control condition. Smoking status was confirmed at 3, 6, 12, and 18 months postrandomization by expired carbon monoxide at ≤ 10 ppm. Staged-care counseling condition plus NRT outperformed brief contact control over time (OR = 4.55, 95% CI 1.04 to 19.93) with abstinence rates of 14.11% and 9.43% at 12 months and 18.4% and 13.21% at 18 months for the intervention and control, respectively.

### Synthesis of Evidence on NRT

Four studies addressed comparative effectiveness of adding single-form NRT (i.e., not combination NRT therapy) to other cotreatments versus an active control for adults with depression. Most trials reported smoking cessation outcomes of 12 months or greater from point of randomization. Of the four studies included in this review, only one intervened with adults with current depression;57 results of other studies are from subgroup analyses. Cotreatments were heterogeneous and ranged from intensive CBT counseling to brief one-time counseling. However, most studies were of good quality and reported a small, positive effect for the use of NRT.

[underlined: Antidepressant therapy + cotreatment versus placebo + cotreatment.] Five trials reported results of adding antidepressants to cotreatments compared to active control condition for smokers with depression. Three of these studies, all of good quality and involving 255 smokers with depression, provided 6-month or greater outcomes data and were included in a meta-analysis.45,54,61 These studies compared antidepressants plus behavioral counseling to behavioral counseling plus placebo (Table 6). Two studies compared antidepressant therapy plus a cotreatment of behavioral counseling and NRT. These studies reported outcomes less than 6 months postrandomization and were not included in the meta-analysis.

Table 6 Smoking Cessation Studies of Antidepressant Therapy Plus Behavioral Counseling Versus Placebo Plus Behavioral Counseling

Study, year | Intervention | Comparator | Follow-up duration
Covey, 2002 | Sertraline + 9 individual in-person smoking cessation behavioral counseling sessions augmented with supportive approach to man-age negative affect associated with quitting smoking | Placebo + 9 individual in-person smoking cessation behavioral counseling sessions augmented with supportive approach to manage negative affect associated with quitting smoking | 34 weeks
Hall, 1998 a | Nortriptyline + 10 session of group CBT smoking cessation counseling or 10 session health education | Placebo + 10 session of group CBT smoking cessation counseling or 10 session health education | 64 weeks
Hayford, 1999 | Bupropion + 11 brief in-person individual counseling sessions | Placebo + 11 brief in-person individual counseling sessions | 12 months

a Factorial design and analysis collapsed across treatment arms.

Participants receiving antidepressants plus behavioral counseling were not more likely to be abstinent compared to participants receiving behavioral counseling plus placebo at 6-month postrandomization (RR = 1.31, 95% CI 0.73 to 2.34, Cochran Q = 0.55, p = 0.76, I^2^ = 0%) (Figure 3).

Figure 3 Risk of Smoking Cessation at Least 6 Months After Start of Antidepressant Therapy Plus Behavioral Counseling Compared With Placebo + Behavioral Counseling

In a study of good quality, Evins and colleagues (2008) tested the efficacy of adding 12 weeks of bupropion to a cotreatment consisting of 8 weeks of transdermal NRT and 13 sessions of group CBT smoking cessation counseling (Table 7).55 All participants had a lifetime history of unipolar depressive disorder (UDD). Results were in the expected direction, favoring antidepressant use in combination with behavioral counseling plus NRT over behavioral counseling plus NRT alone (36% versus 31%; p-value NR). However, participants randomized to receive bupropion were no more likely to achieve smoking abstinence at end of treatment in intention-to-treat (ITT) analysis with dropouts considered smokers. Moreover, smoking abstinence was associated with depressive symptoms, regardless of antidepressant use.

Table 7 Smoking Cessation Studies of Antidepressant Therapy Plus Behavioral Counseling Plus NRT Versus Placebo Plus Behavioral Counseling Plus NRT

Study, year | Intervention | Comparator | Follow-up duration
Evins, 2008 | Bupropion + 13 group CBT smoking cessation counseling + NRT patch | Placebo + 13 group CBT smoking cessation counseling + NRT patch | 13 weeks
Saules, 2004 | Fluoxetine + 6 group CBT smoking cessation counseling + NRT patch | Placebo + 6 group CBT smoking cessation counseling + NRT patch | 12 months

Saules and colleagues (2004) also tested the addition of an antidepressant to a cotreatment of NRT and behavioral counseling (Table 7).62 This study was of fair quality. Participants in the intervention arm received 10 weeks of transdermal NRT plus 14 weeks of either 20 or 40 mg of fluoxetine in combination with 6 weeks of group CBT smoking cessation counseling. Again, results were in the expected direction and favored the addition of antidepressant therapy. However, among participants who were history positive for MDD (n = 30), Saules found no significant differences in abstinence rates when fluoxetine was added to NRT and intensive behavioral counseling.

### Synthesis of Evidence on Antidepressants

Five studies addressed comparative effectiveness of adding antidepressants to other cotreatments versus an active control (e.g., counseling + NRT + placebo) for adults with depression. For included studies, antidepressants were prescribed at therapeutic doses. Only two included studies recruited participants with histories of MDD;54,55 results of other studies are from subgroup analyses. All cotreatments included multisession counseling, and four studies were of good quality. However, there was heterogeneity in antidepressant type across included studies. Only one used bupropion, the only antidepressant with an FDA indication for smoking cessation. Overall, we did not find enough evidence to support adding antidepressants to other smoking cessation cotreatments in order to improve smoking cessation rates among persons with depression.

[underlined: Mood management treatment + cotreatment versus cotreatment/active control.] Six trials reported results of adding mood management treatments to behavioral counseling (Table 8). Other cotreatments given to all participants include NRT,44,58–60 nortriptyline,45 or NRT plus bupropion or paroxetine.59 Five of these studies, involving 402 smokers with depression, provided sufficient data for meta-analysis.44,45,53,58,60

Table 8 Smoking Cessation Studies With a Mood Management Treatment Component

Study, year | Intervention | Comparator | Follow-up duration
Mood management treatment + behavioral counseling versus behavioral counseling
Brown, 2001 | 8 group sessions of depression and smoking cessation CBT | 8 group sessions of smoking cessation CBT | 12 months
Mood management treatment + behavioral counseling + NRT versus behavioral counseling + NRT
Hall, 1994 | 5 group sessions of CBT mood management + 5 group sessions of smoking cessation counseling + nicotine gum | 5 group sessions of smoking cessation counseling + nicotine gum | 52 weeks
Hall, 1996 a | 5 group sessions of CBT mood management + 5 group sessions of smoking cessation counseling + nicotine gum | 10 sessions of standard group smoking cessation health education + nicotine gum | 52 weeks
MacPherson, 2010 | 8 group sessions of smoking cessation CBT that included behavioral activation therapy + NRT patch | 8 group sessions of smoking cessation CBT + NRT patch | 26 weeks
Mood management treatment + behavioral counseling + NRT/antidepressant versus control
Duffy, 2006 | 9 to 11 sessions of combined smoking, depression, alcohol abuse telephone CBT + bupropion + NRT (if failed bupropion monotherapy in the past) OR NRT + paroxetine (if failed bupropion in the past for depression) | One-time behavioral counseling and referral to appropriate services for substance use/abuse and/or depression | 6 months
Hall, 1998 a | 5 group sessions of CBT mood management + 5 group sessions of smoking cessation counseling + nortriptyline or placebo | 10 session health education + nortriptyline or placebo | 64 weeks

a Factorial design and analysis collapsed across treatment arms.

All studies included in the meta-analysis were in the expected direction, favoring the addition of mood management treatment to smoking cessation cotreatments (RR = 1.45, 95% CI 1.01 to 2.07, Cochran Q = 2.16, p = 0.71, I^2^ = 0%). Subgroup analysis suggests smoking cessation may be more likely when mood management treatment was added to cotreatments that included NRT or antidepressants in addition to behavioral counseling (RR = 1.66, 95% CI 0.95 to 2.90, Cochran Q = 1.8, p = 0.62, I^2^ = 0%) (Figure 4). However, confidence intervals overlap, and this contrast was not statistically significant.

Figure 4 Risk of Smoking Cessation at Least 6 Months After Start of Mood Management Treatment Plus Cotreatment Compared to Active Control

In a study of good quality, Duffy and colleagues (2006) tested a combined smoking, depression, and alcohol abuse CBT counseling protocol for head-and-neck cancer survivors.59 Smokers who were depressed were offered NRT and bupropion or paroxetine. Content was delivered by telephone over the course of 9 to 11 counseling sessions. One-time behavioral counseling and referral to appropriate follow-up services served as the comparator condition. Among participants who were smokers and depressed at baseline (n = 64), 51% were nonsmokers at 6 months from end of treatment compared to 17% in the control arm (p-value NR). Smoking status was verified by self-report only.

### Synthesis of Evidence on Mood Management Treatment

Six trials addressed comparative effectiveness of adding mood management treatments to other smoking cessation cotreatments versus an active control for adults with depression. All trials reported smoking cessation outcomes at 6 months or greater from point of randomization. Four of these trials were of good quality. Of the five trials included in the meta-analysis, only two studies recruited participants with either a history of MDD53 or elevated depressive symptoms.58 Results of other studies are from subgroup analyses. Overall, results indicate a small, positive effect for the addition of mood management treatment to smoking cessation cotreatments.

[underlined: Other intervention strategies.] Three additional trials tested other types of interventions. These are summarized below and in Table 9.

Table 9 Other Smoking Cessation Intervention Strategies Studies

Study, year | Intervention | Comparison | Follow-up duration
Covey, 1999 | Naltrexone + 6 individual in-person behavioral counseling sessions | Placebo + 6 individual in-person behavioral counseling sessions | 6 months
Munoz, 1997 | Mailed smoking cessation guide + mood management guide | Mailed smoking cessation guide + mood management guide at 3 months delayed | 6 months
Vickers, 2009 | 10 in-person individual exercise counseling sessions that include brief smoking cessation counseling + NRT | 10 in-person individual health education sessions that include brief smoking cessation counseling + NRT | 24 weeks

In a study of fair quality, Covey and colleagues (1999) tested behavioral counseling plus a long-acting opiate antagonist, naltrexone, as a smoking cessation aid.63 Participants received six individual brief behavioral counseling sessions. Participants in the control arm received the same counseling plus placebo. Smoking status was verified by blood cotinine level of < 15 ng/ml. Of the 36 participants with a history of MDD, results favored use of naltrexone in combination with counseling over counseling plus placebo (28.6% versus 9.1%; p-value NR).

Munoz and colleagues (1997) tested the efficacy of a self-administered mood management intervention plus smoking cessation guide compared to a smoking cessation guide alone delivered through the mail for Spanish-speaking smokers.51 To be eligible for the trial, participants needed to indicate that they were either “completely” or “very” sure they wanted to quit smoking in the next 3 months. The smoking cessation guide was a 36-page booklet from the National Cancer Institute and contained tips on how to quit smoking. The mood management treatment consisted of relaxation exercises, self-monitoring booklet, and pleasant activity guide. An audio cassette explained how to use the materials. Among participants with a history of MDE, the addition of mailed mood management content improved cessation rates over the mailed smoking cessation guide (38.5% versus 7.4%; p = 0.01) at 6 months postrandomization. For smokers with current MDE, no significant differences were found (17.9% versus 8.0%; p = 0.15). This study was of fair quality.

In another fair study, Vickers and colleagues (2009) conducted a small randomized pilot to test the feasibility of behavioral counseling to promote exercise as a smoking cessation intervention for depressed female smokers.56 Women were randomized to receive brief smoking cessation counseling plus 6 weeks of transdermal NRT, plus either 10 weeks of CBT to encourage exercise or a health education contact control condition. The intervention was feasible but did not significantly improve smoking cessation rates compared to the health education control (17% versus 23%; p = 0.75).

### Synthesis of Evidence on Other Intervention Strategies

We identified three other types of smoking cessation strategies, each with only one RCT. Covey and colleagues (1999) and Munoz both reported positive results for participants with depression. However, studies were of fair quality (e.g., no ITT analysis, lack of detail on study measures, randomization and allocation concealment procedures not well described) and with select populations (e.g., Spanish speakers), which limits confidence in the estimates of effects and applicability of results to other populations. Results of Vickers and colleagues (2009) demonstrated no effect for using exercise counseling as a smoking cessation intervention strategy for smokers with depression.

## KEY QUESTION 2 For patients with a history of a depressive disorder or current significant depressive symptoms, are there differential effects of smoking cessation strategies by depression status (i.e., history of MDD, current depressive symptoms, current MDD)?

Only two studies provided sufficient information to report differential effectiveness of smoking cessation intervention strategies by depression status. For both reports, study researchers conducted subgroup analysis only; no treatment by depression interaction effects were directly tested.

Evins and colleagues (2008) recruited 199 smokers who had a lifetime diagnosis of UDD. Participants were randomized to 12 weeks of bupropion versus placebo. Both groups received a cotreatment consisting of 8 weeks of transdermal NRT and 13 sessions of group CBT smoking cessation counseling.55 Among participants who were history positive for unipolar depression (n = 109), 39% in the bupropion arm and 32% in the control arm were abstinent at the end of trial (p-value NS). Among participants with current depression (n = 90), bupropion did not significantly improve smoking cessation rates compared to cotreatment control condition (33% versus 31%; p-value NS).

Munoz and colleagues (1997) tested the efficacy of a mailed self-administered mood management intervention plus smoking cessation guide compared to only a smoking cessation guide for Spanish-speaking smokers.51 The addition of mailed mood management content improved cessation rates over the mailed smoking cessation guide (38.5% versus 7.4%; p = 0.01) at 6 months postrandomization for participants with a history of MDE. Smokers with current MDE did not experience significant differences (17.9% versus 8.0%; p = 0.15).

## KEY QUESTION 3 For patients with a history of a depressive disorder or current significant depressive symptoms, are there differential effects of smoking cessation strategies by gender?

Only one included study reported a significant treatment by gender interaction among study participants with a history of or current depression.63 Covey and colleagues (1999) found a significant treatment by gender by depression interaction. Women with past histories of MDD (n = 26) experienced higher quit rates when randomized to receive naltrexone in combination with six sessions of individual behavioral counseling compared to women with depression receiving placebo control at 6 months (22.2% versus 0%; p = 0.04). Men with past histories of MDD (n = 10) did not experience significantly higher quit rates with naltrexone at 6 months.

## KEY QUESTION 4 For patients with a history of a depressive disorder or current significant depressive symptoms, does treatment effectiveness differ by whether smoking cessation/depression treatments are delivered concurrently or sequentially?

No studies directly compared smoking cessation and depression treatments delivered concurrently versus sequentially.

## KEY QUESTION 5 What is the nature and frequency of adverse effects of smoking cessation treatments in patients with a history of a depressive disorder or current significant depressive symptoms?

Table 10 details reported adverse effects of the 16 included trials. Overall, 11 studies did not provide information on the nature and frequency of adverse effects of treatments. Of the five studies that reported adverse effects, three provided some level of detail about the magnitude and significance of adverse effects; other studies reported too few cases to conduct statistical tests. These three studies all evaluated the addition of antidepressants with other smoking cessation treatments. In two of the three studies, selected adverse effects were more common in patients randomized to antidepressants.

Table 10 Adverse Effects of Included Studies

Study, year | Intervention | Adverse effects reported^a^ (% reported in intervention versus control) | Change in depressive symptoms^b^
Brown, 2001 | 8 group sessions of depression and smoking cessation CBT | NR | No difference between intervention and control arms
Covey, 1999 | Naltrexone + 6 individual in-person behavioral counseling sessions | Panic attack, malaise, sleeplessness, concentration difficulty, nau-sea and vomiting, disoriented and shaky, spaciness, dizzy, abdominal pain, lightheadedness, shortness of breath | NR
Covey, 2002 | Sertraline + 9 individual in-person smoking cessation behavioral counseling sessions augmented with supportive approach to manage negative affect associated with quitting smoking | NR | No difference between intervention and control arms
Duffy, 2006 | 9 to 11 sessions of combined smoking, depression, alcohol abuse telephone CBT + bupropion + NRT (if failed bupropion monotherapy in the past) OR NRT + paroxetine (if failed bupropion in the past for depression) | NR | No difference between intervention and control arms
Evins, 2008 | Bupropion + 13 group sessions of CBT smoking cessation counseling + NRT patch | NR | No difference between intervention and control arms
Hall, 1994 | 5 group sessions of CBT mood management + 5 group sessions of smoking cessation counseling + nicotine gum | NR | NR
Hall, 1996 | 5 group sessions of CBT mood management + 5 group sessions of smoking cessation counseling + nicotine gum | NR | No difference between intervention and control arms
Hall, 1998 | 5 group sessions of CBT mood management + 5 group sessions of smoking cessation counseling + nortriptyline | Dry mouth (78% vs 33%)^c^, lightheadedness (49% vs 22%)^c^, shaky hands (23% vs 11%)^c^, blurry vision (16% vs 6%)^c^ | NR
Hall, 2006 | Transdermal nicotine patch (or bupropion if failed NRT) + staged motivational feedback + 6 sessions of individual CBT smoking cessation counseling | NR | No difference between intervention and control arms
Hayford, 1999 | Bupropion + 11 brief in-person individual counseling sessions | Headache (29% vs 31–33%), insomnia (21% vs 30–35%)^c^, rhinitis (17% vs 10 to 12%), dry mouth (5% vs 13%)^c^, increased anxiety (11% vs 5–7%) | NR
Kinnunen, 1996 | Nicotine gum + one-time brief individual behavioral counseling | NR | Decrease in NRT gum arm and no change in placebo arm
Kinnunen, 2008 | Nicotine gum + 9 brief in-person individual counseling sessions | Heart palpitations, nausea, vomiting, dizziness, breathing difficulties, tongue blisters, damage to dental work, sore jaw^d^ | NR
MacPherson, 2010 | 8 group sessions of smoking cessation CBT that included behavioral activation therapy + NRT patch | NR | Greater decrease in intervention arm compared to control arm
Munoz, 1997 | Mailed smoking cessation guide + mood management guide | NR | NR
Saules, 2004 | Fluoxetine + 6 group sessions of CBT smoking cessation counseling + NRT patch | Adverse effects not more common in intervention arms but did not list types | NR
Vickers, 2009 | 10 in-person individual exercise counseling sessions that include brief smoking cessation counseling + NRT | NR | Decrease in health education arm and increase in exercise counseling arm

a Adverse effects reported for all subjects in trial.

b For participants within depressed subgroup, statistically significant change in depressive symptoms from baseline to follow-up.

c Statistically significant and greater proportion affected in intervention arm compared to proportion affected in control arm.

d Less than 2% of low-nicotine dependent and 6% of high-nicotine dependent participants in the intervention arms experienced most common NRT gum adverse effects (i.e., heart palpitations, nausea, vomiting, dizziness).

Abbreviations: CBT = cognitive behavioral therapy, NR = not reported, NRT = nicotine replacement therapy

Table 10 also summarizes change in depressive symptoms from baseline to follow-up when comparing intervention and control arms among participants classified as depressed at baseline. Seven trials did not report changes in depressive symptoms from baseline to follow-up per arm for participants classified as depressed at study entry. Six studies reported no significant differences. Of three studies that reported significant differences, only Vickers and colleagues (2009) reported more favorable changes in depressive symptoms associated with the control arm compared to the intervention arm. Kinnunen and colleagues (1996) and MacPherson and colleagues (2010) reported more favorable changes in depressive symptoms associated with the intervention arms.