# REFERENCES

1 Danaei G, Ding EL, Mozaffarian D, et al. The preventable causes of death in the United States: comparative risk assessment of dietary, lifestyle, and metabolic risk factors. PLoS Med. 2009;6(4):e1000058. [pmid: 19399161].
2 Mokdad AH, Marks JS, Stroup DF, et al. Actual causes of death in the United States, 2000. JAMA. 2004;291(10):1238-45. [pmid: 15010446].
3 Cigarette smoking among adults--United States, 2006. MMWR Morb Mortal Wkly Rep. 2007;56(44):1157-61. [pmid: 17989644].
4 Grant BF, Hasin DS, Chou SP, et al. Nicotine dependence and psychiatric disorders in the United States: results from the national epidemiologic survey on alcohol and related conditions. Arch Gen Psychiatry. 2004;61(11):1107-15. [pmid: 15520358].
5 Lasser K, Boyd JW, Woolhandler S, et al. Smoking and mental illness: A population-based prevalence study. JAMA. 2000;284(20):2606-10. [pmid: 11086367].
6 Ziedonis D, Hitsman B, Beckham JC, et al. Tobacco use and cessation in psychiatric disorders: National Institute of Mental Health report. Nicotine Tob Res. 2008;10(12):1691-715. [pmid: 19023823].
7 Hall SM, Prochaska JJ. Treatment of smokers with co-occurring disorders: emphasis on integration in mental health and addiction treatment settings. Annu Rev Clin Psychol. 2009;5:409-31. [pmid: 19327035].
8 Hamlett-Berry K, Davison J, Kivlahan DR, et al. Evidence-based national initiatives to address tobacco use as a public health priority in the Veterans Health Administration. Mil Med. 2009;174(1):29-34. [pmid: 19216295].
9 Black DW, Carney CP, Forman-Hoffman VL, et al. Depression in veterans of the first Gulf War and comparable military controls. Ann Clin Psychiatry. 2004;16(2):53-61. [pmid: 15328898].
10 Institute of Medicine. Combating tobacco use in the military and veteran populations. Washington, DC. The National Academies Press. 2009.
11 Fiedler N, Ozakinci G, Hallman W, et al. Military deployment to the Gulf War as a risk factor for psychiatric illness among US troops. Br J Psychiatry. 2006;188:453-9. [pmid: 16648532].
12 Desai MM, Rosenheck RA, Craig TJ. Case-finding for depression among medical outpatients in the Veterans Health Administration. Med Care. 2006;44(2):175-81. [pmid: 16434917].
13 Currie SR, Hodgins DC, el-Guebaly N, et al. Influence of depression and gender on smoking expectancies and temptations in alcoholics in early recovery. J Subst Abuse. 2001;13(4):443-58. [pmid: 11775075].
14 Ischaki E, Gratziou C. Smoking and depression: Is smoking cessation effective?. Ther Adv Respir Dis. 2009;3(1):31-8. [pmid: 19293201].
15 Berlin I, Covey LS. Pre-cessation depressive mood predicts failure to quit smoking: the role of coping and personality traits. Addiction. 2006;101(12):1814-21. [pmid: 17156181].
16 Breslau N, Johnson EO. Predicting smoking cessation and major depression in nicotine-dependent smokers. Am J Public Health. 2000;90(7):1122-7. [pmid: 10897192].
17 Kenney BA, Holahan CJ, Holahan CK, et al. Depressive symptoms, drinking problems, and smoking cessation in older smokers. Addict Behav. 2009;34(6–7):548-53. [pmid: 19372009].
18 Cinciripini PM, Wetter DW, Fouladi RT, et al. The effects of depressed mood on smoking cessation: mediation by postcessation self-efficacy. J Consult Clin Psychol. 2003;71(2):292-301. [pmid: 12699023].
19 Wiesbeck GA, Kuhl HC, Yaldizli O, et al. Tobacco smoking and depression--results from the WHO/ISBRA study. Neuropsychobiology. 2008;57(1–2):26-31. [pmid: 18424908].
20 Kinnunen T, Haukkala A, Korhonen T, et al. Depression and smoking across 25 years of the Normative Aging. Int J Psychiatry Med. 2006;36(4):413-26. [pmid: 17407995].
21 Glassman AH, Covey LS, Stetner F, et al. Smoking cessation and the course of major depression: a follow-up study. Lancet. 2001;357(9272):1929-32. [pmid: 11425414].
22 Niaura R, Britt DM, Shadel WG, et al. Symptoms of depression and survival experience among three samples of smokers trying to quit. Psychol Addict Behav. 2001;15(1):13-7. [pmid: 11255933].
23 Pomerleau CS, Zucker AN, Stewart AJ. Characterizing concerns about post-cessation weight gain: Results from a national survey of women smokers. Nicotine Tob Res. 2001;3(1):51-60. [pmid: 11260811].
24 Tsoh JY, Humfleet GL, Munoz RF, et al. Development of major depression after treatment for smoking cessation. Am J Psychiatry. 2000;157(3):368-74. [pmid: 10698811].
25 Siru R, Hulse GK, Tait RJ. Assessing motivation to quit smoking in people with mental illness: a review. Addiction. 2009;104(5):719-33. [pmid: 19413788].
26 Prochaska JJ, Rossi JS, Redding CA, et al. Depressed smokers and stage of change: implications for treatment interventions. Drug Alcohol Depend. 2004;76(2):143-51. [pmid: 15488338].
27 Hitsman B, Moss TG, Montoya ID, et al. Treatment of tobacco dependence in mental health and addictive disorders. Can J Psychiatry. 2009;54(6):368-78. [pmid: 19527557].
28 Hall SM. Nicotine interventions with comorbid populations. Am J Prev Med. 2007;33(6 Suppl):S406-13. [pmid: 18021916].
29 Stead LF, Perera R, Lancaster T. Telephone counselling for smoking cessation. Cochrane Database Syst Rev. 2006;3:CD002850. [pmid: 16855992].
30 Shiffman S, Ferguson SG. Nicotine patch therapy prior to quitting smoking: a meta-analysis. Addiction. 2008;103(4):557-63. [pmid: 18339101].
31 Baddoura R, Wehbeh-Chidiac C. Prevalence of tobacco use among the adult Lebanese population. East Mediterr Health J. 2001;7(4–5):819-28. [pmid: 15332785].
32 Stead LF, Bergson G, Lancaster T. Physician advice for smoking cessation. Cochrane Database Syst Rev. 2008(2):CD000165. [pmid: 18425860].
33 Lancaster T, Stead LF. Individual behavioural counselling for smoking cessation. Cochrane Database Syst Rev. 2005(2):CD001292. [pmid: 15846616].
34 Stead LF, Lancaster T. Group behaviour therapy programmes for smoking cessation. Cochrane Database Syst Rev. 2005(2):CD001007. [pmid: 15846610].
35 Stead LF, Perera R, Bullen C, et al. Nicotine replacement therapy for smoking cessation. Cochrane Database Syst Rev. 2008(1):CD000146. [pmid: 18253970].
36 Hughes JR, Stead LF, Lancaster T. Antidepressants for smoking cessation. Cochrane Database Syst Rev. 2007(1):CD000031. [pmid: 17253443].
37 Fiore MC, Jaén CR, Baker TB, et al. Treating Tobacco Use and Dependence: 2008 Update Quick Reference Guide for Clinicians. Rockville, MD. US Department of Health and Human Services, Public Health Service. April. 2009. Available at: http://www.ahrq.gov/clinic/tobacco/tobaqrg.pdf. Accessed November 2010.
38 Rabius V, Pike KJ, Hunter J, et al. Effects of frequency and duration in telephone counselling for smoking cessation. Tob Control. 2007;16(Suppl 1):i71-4. [pmid: 18048636].
39 An LC, Zhu SH, Nelson DB, et al. Benefits of telephone care over primary care for smoking cessation: a randomized trial. Arch Intern Med. 2006;166(5):536-42. [pmid: 16534040].
40 Weinberger AH, Maciejewski PK, McKee SA, et al. Gender differences in associations between lifetime alcohol, depression, panic disorder, and posttraumatic stress disorder and tobacco withdrawal. Am J Addict. 2009;18(2):140-7. [pmid: 19283566].
41 Gelenberg AJ, de Leon J, Evins AE, et al. Smoking cessation in patients with psychiatric disorders. Prim Care Companion J Clin Psychiatry. 2008;10(1):52-8. [pmid: 18311422].
42 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed November 11, 2010.
43 West R, Hajek P, Stead L, et al. Outcome criteria in smoking cessation trials: proposal for a common standard. Addiction. 2005;100(3):299-303. [pmid: 15733243].
44 Hall SM, Munoz RF, Reus VI, et al. Mood management and nicotine gum in smoking treatment: a therapeutic contact and placebo-controlled study. J Consult Clin Psychol. 1996;64(5):1003-9. [pmid: 8916629].
45 Hall SM, Reus VI, Munoz RF, et al. Nortriptyline and cognitive-behavioral therapy in the treatment of cigarette smoking. Arch Gen Psychiatry. 1998;55(8):683-90. [pmid: 9707377].
46 Cochran WG. The Combination of Estimates from Different Experiments. Biometrics. 1954;10(1):101-129.
47 Fleiss JL. Analysis of data from multiclinic trials. Control Clin Trials. 1986;7(4):267-75. [pmid: 3802849].
48 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
49 Higgins JP, Greenberg S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2 [updated September 2009]. The Cochrane Collaboration. 2009. Available from www.cochrane-handbook.org.
50 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
51 Munoz RF, Marin BV, Posner SF, et al. Mood management mail intervention increases abstinence rates for Spanish-speaking Latino smokers. Am J Community Psychol. 1997;25(3):325-43. [pmid: 9332966].
52 Kinnunen T, Doherty K, Militello FS, et al. Depression and smoking cessation: characteristics of depressed smokers and effects of nicotine replacement. J Consult Clin Psychol. 1996;64(4):791-8. [pmid: 8803370].
53 Brown RA, Kahler CW, Niaura R, et al. Cognitive-behavioral treatment for depression in smoking cessation. J Consult Clin Psychol. 2001;69(3):471-80. [pmid: 11495176].
54 Covey LS, Glassman AH, Stetner F, et al. A randomized trial of sertraline as a cessation aid for smokers with a history of major depression. Am J Psychiatry. 2002;159(10):1731-7. [pmid: 12359680].
55 Evins AE, Culhane MA, Alpert JE, et al. A controlled trial of bupropion added to nicotine patch and behavioral therapy for smoking cessation in adults with unipolar depressive disorders. J Clin Psychopharmacol. 2008;28(6):660-6. [pmid: 19011435].
56 Vickers KS, Patten CA, Lewis BA, et al. Feasibility of an exercise counseling intervention for depressed women smokers. Nicotine Tob Res. 2009;11(8):985-95. [pmid: 19541948].
57 Hall SM, Tsoh JY, Prochaska JJ, et al. Treatment for cigarette smoking among depressed mental health outpatients: a randomized clinical trial. Am J Public Health. 2006;96(10):1808-14. [pmid: 17008577].
58 MacPherson L, Tull MT, Matusiewicz AK, et al. Randomized controlled trial of behavioral activation smoking cessation treatment for smokers with elevated eepressive symptoms. J Consult Clin Psychol. 2010;78(1):55-61. [pmid: 20099950].
59 Duffy SA, Ronis DL, Valenstein M, et al. A tailored smoking, alcohol, and depression intervention for head and neck cancer patients. Cancer Epidemiol Biomarkers Prev. 2006;15(11):2203-8. [pmid: 17119047].
60 Hall SM, Munoz RF, Reus VI. Cognitive-behavioral intervention increases abstinence rates for depressive-history smokers. J Consult Clin Psychol. 1994;62(1):141-6. [pmid: 8034816].
61 Hayford KE, Patten CA, Rummans TA, et al. Efficacy of bupropion for smoking cessation in smokers with a former history of major depression or alcoholism. Br J Psychiatry. 1999;174:173-8. [pmid: 10211174].
62 Saules KK, Schuh LM, Arfken CL, et al. Double-blind placebo-controlled trial of fluoxetine in smoking cessation treatment including nicotine patch and cognitive-behavioral group therapy. Am J Addict. 2004;13(5):438-46. [pmid: 15764422].
63 Covey LS, Glassman AH, Stetner F. Naltrexone effects on short-term and long-term smoking cessation. J Addict Dis. 1999;18(1):31-40. [pmid: 10234561].
64 Kinnunen T, Korhonen T, Garvey AJ. Role of nicotine gum and pretreatment depressive symptoms in smoking cessation: twelve-month results of a randomized placebo controlled trial. Int J Psychiatry Med. 2008;38(3):373-89. [pmid: 19069579].
65 Katon WJ. Clinical and health services relationships between major depression, depressive symptoms, and general medical illness. Biol Psychiatry. 2003;54(3):216-26. [pmid: 12893098].
66 John U, Meyer C, Rumpf HJ, et al. Depressive disorders are related to nicotine dependence in the population but do not necessarily hamper smoking cessation. J Clin Psychiatry. 2004;65(2):169-76. [pmid: 15003069].
67 Vickers KS, Patten CA, Clark MM, et al. Exercise intervention for women with depressive symptoms interested in smoking cessation. Society for Research on Nicotine and Tobacco 11th Annual Meeting. 20–23 March 2005. Prague, Czech Republic. 2005.
68 Nides M, Glover ED, Reus VI, et al. Varenicline versus bupropion SR or placebo for smoking cessation: a pooled analysis. Am J Health Behav. 2008;32(6):664-75. [pmid: 18442345].
69 Nides M. Update on Pharmacologic Options for Smoking Cessation Treatment. Am J Med. 2008;121:S20-31. [pmid: 18342163].
70 Campbell AR, Anderson KD. Mental health stability in veterans with posttraumatic stress disorder receiving varenicline. Am J Health Syst Pharm. 2010;67(21):1832-7. [pmid: 20966147].
71 Haaga DA, Thorndike FP, Friedman-Wheeler DG, et al. Cognitive coping skills and depression vulnerability among cigarette smokers. Addict Behav. 2004;29(6):1109-22. [pmid: 15236811].
72 Kahler CW, Brown RA, Ramsey SE, et al. Negative mood, depressive symptoms, and major depression after smoking cessation treatment in smokers with a history of major depressive disorder. J Abnorm Psychol. 2002;111(4):670-5. [pmid: 12428781].
73 Kahler CW, Brown RA, Strong DR, et al. History of major depressive disorder among smokers in cessation treatment: associations with dysfunctional attitudes and coping. Addict Behav. 2003;28(6):1033-47. [pmid: 12834649].
74 Carmody TP. Affect regulation, nicotine addiction, and smoking cessation. J Psychoactive Drugs. 1992;24(2):111-22. [pmid: 1506996].
75 Hall SM, Munoz RF, Reus VI, et al. Nicotine, negative affect, and depression. J Consult Clin Psychol. 1993;61(5):761-7. [pmid: 7902368].
76 Hurt RD, Sachs DP, Glover ED, et al. A comparison of sustained-release bupropion and placebo for smoking cessation. N Engl J Med. 1997;337(17):1195-202. [pmid: 9337378].
77 Hughes JR, Keely J, Naud S. Shape of the relapse curve and long-term abstinence among untreated smokers. Addiction. 2004;99(1):29-38. [pmid: 14678060].
78 Haas AL, Munoz RF, Humfleet GL, et al. Influences of mood, depression history, and treatment modality on outcomes in smoking cessation. J Consult Clin Psychol. 2004;72(4):563-70. [pmid: 15301640].
79 Williams JW Jr, Pignone M, Ramirez G, et al. Identifying depression in primary care: a literature synthesis of case-finding instruments. Gen Hosp Psychiatry. 2002;24(4):225-37. [pmid: 12100833].
80 Sun X, Briel M, Walter SD, et al. Is a subgroup effect believable? Updating criteria to evaluate the credibility of subgroup analyses. BMJ. 2010;340:c117. [pmid: 20354011].
81 Pomerleau CS, Brouwer RJ, Pomerleau OF. Emergence of depression during early abstinence in depressed and non-depressed women smokers. J Addict Dis. 2001;20(1):73-80. [pmid: 11286432].
82 Shah SD, Wilken LA, Winkler SR, et al. Systematic review and meta-analysis of combination therapy for smoking cessation. J Am Pharm Assoc (2003). 2008;48(5):659-65. [pmid: 18826906].