# METHODS

## TOPIC DEVELOPMENT

This review was commissioned by the Department of Veterans Affairs’ Evidence-based Synthesis Program. The topic was selected after a formal topic nomination and prioritization process that included representatives from the Office of Mental Health Services, Health Services Research and Development, the Mental Health QUERI, and the Office of Mental Health and Primary Care Integration. The key research questions for this review were developed and refined after preliminary review of published peer-reviewed literature and consultation with VA and non-VA experts to select the patients and subgroups, interventions, outcomes, and settings addressed in this review.

The final key questions were as follows:

- Key Question 1: For patients with a history of a depressive disorder or current significant depressive symptoms, what is the comparative effectiveness of different smoking cessation strategies on smoking abstinence rates?
- Key Question 2: For patients with a history of a depressive disorder or current significant depressive symptoms, are there differential effects of smoking cessation strategies by depression status (i.e., history of MDD, current depressive symptoms, current MDD)?
- Key Question 3:For patients with a history of a depressive disorder or current significant depressive symptoms, are there differential effects of smoking cessation strategies by gender?
- Key Question 4: For patients with a history of a depressive disorder or current significant depressive symptoms, does treatment effectiveness differ by whether smoking cessation/ depression treatments are delivered concurrently or sequentially?
- Key Question 5: What is the nature and frequency of adverse effects of smoking cessation treatments in patients with a history of a depressive disorder or current significant depressive symptoms?

We developed and followed a standard protocol for all steps of this review. Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic Framework

## SEARCH STRATEGY

We searched for English-language publications in MEDLINE (via PubMed), Embase, PsycINFO, and the Cochrane Library from database inception through March 10, 2010. We developed search strategies in consultation with a master librarian. The search terms and MeSH headings for the search strategies appear in Appendix A. We supplemented electronic searching by examining the bibliographies of included studies.

## STUDY SELECTION

Using prespecified inclusion/exclusion criteria, two trained researchers reviewed the list of titles and selected articles for further review. Each article retrieved was reviewed with a brief screening form used to determine eligibility. To be included in our evidence report, a study had to (1) be a randomized controlled trial (RCT), (2) compare two or more smoking cessation interventions or compare intervention to control, and (3) report smoking cessation outcomes in adults with depression. Detailed eligibility criteria are described in Table 1.

Table 1 Summary of Inclusion and Exclusion Criteria

Study characteristic | Inclusion criteria | Exclusion criteria
Study design | RCTs or a secondary data analysis from RCTs of smoking cessation interventions | Non-English language publication, cross-sectional studies
Population | Adults age 18 and over with a history of a depressive disorder or current significant depressive symptoms^a^ | Pregnant women, adolescents, postpartum depression, depressive symptoms secondary to another primary condition (e.g., substance abuse, schizophrenia)
Interventions | Any patient-level smoking cessation strategies (e.g., self-help, quit lines, physician or brief advice, behavioral counseling, pharmacologic therapies) alone or in combination with other strategies | Policy-level interventions (e.g., smoking bans), mass media campaigns
Comparators | Active comparators or control (e.g., usual care or placebo) | None
Setting | Outpatient (e.g., mental health clinics, primary care) or delivered through remote communication technologies (e.g., telephone, Web) | Hospital-based (inpatient) interventions
Outcome | KQs 1–4: Smoking abstinence reported at ≥ 3 months postrandomization KQ 5: Adverse effects including behavioral symptoms, increased anxiety, depression^b^ | Relapse prevention^c^

a We define significant depressive symptoms as meeting a designated threshold on a validated assessment instrument (e.g., CES-D, BDI).

b We considered depression as an adverse effect when participants moved from depressive symptoms to a depressive disorder, or when the intervention arm showed significantly more depressive symptoms compared to a decrease in symptoms in the comparator condition.

c Intervention strategies that reduce the likelihood of recent quitters returning to smoking.

Abbreviations: BDI = Beck Depression Inventory, CES-D = Center for Epidemiologic Studies-Depression Scale, RCT = randomized controlled trial

## DATA ABSTRACTION

A trained researcher abstracted data from published reports into evidence tables; a second reviewer overread the evidence tables. We resolved disagreements by consensus among the first and second reviewer or by obtaining a third reviewer’s opinion when consensus could not be reached. We abstracted the following data from included studies: (1) Study design and setting, (2) eligibility criteria, (3) exclusion criteria, (4) sample size, (5) demographics, (6) duration of follow-up, (7) depression clinical category, (8) baseline smoking characteristics (e.g., cigarettes per day, tobacco dependence), (9) method used to assess depression, (10) intervention characteristics (e.g., mode, frequency, dose, core therapy components), (11) outcome measures, (12) results, and (13) adverse effects.

## QUALITY ASSESSMENT

We assessed risk of bias using the key quality criteria described in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter referred to as the General Methods Guide),42 adapted for this specific topic. We abstracted data on adequacy of randomization and allocation concealment, comparability of groups at baseline, blinding, completeness of follow-up and differential loss to follow-up, whether incomplete data were addressed appropriately, validity of outcome measures, and conflict of interest. Using these data elements, we assigned a summary quality score of Good, Fair, or Poor to individual RCTs.

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by key question and intervention, as appropriate. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each key question.

When study designs and outcomes reported were similar, we estimated pooled risk ratios with 95% confidence intervals (CIs) by using a random effects model with the Mantel-Haenszel method. For these analyses, we classified each intervention element into the following categories: Antidepressants, nicotine replacement therapy (NRT), brief smoking cessation counseling, behavioral counseling for smoking cessation, or behavioral mood management treatment. We defined brief smoking cessation counseling as counseling that was similar in content to what may be given during a physician visit. We defined behavioral counseling for smoking cessation as multisession individual or group therapy that used behavioral strategies, such as those common in cognitive behavioral therapy (CBT), to influence tobacco use. Behavioral mood management treatment was defined as group or individual counseling intended to influence negative mood and improve depression symptomatology above and beyond standard smoking cessation counseling.

Using these intervention categories, there were sufficient studies to perform meta-analyses for two comparisons: Mood management versus control and antidepressants versus control. Other comparisons were synthesized qualitatively. All studies that were analyzed quantitatively used behavioral counseling for smoking cessation in the intervention and control arms. For the mood management comparison, we subgrouped studies using NRT alone or in combination with antidepressants.

The primary outcome was smoking abstinence without smoking relapse. Smoking abstinence was defined as smoking cessation collected as (1) point prevalence abstinence (e.g., in past 7 days) or (2) extended abstinence (e.g., since quit date or last previous follow-up). We included only one effect size per study. Therefore, we assessed the most distal and rigorous (extended abstinence over point prevalence) outcomes reported and categorized as short-term (3 < 6 months) or long-term (≥6 months) confirmed by self-report, biochemical validation, or both. Our outcome was informed by outcomes used in the Cochrane Collaborative reviews, which are based on the Russell Standard.43 The U.S. Department of Health and Human Services Tobacco Use and Dependence Guideline Panel recommended a minimum of a 6-month period to assess treatment differences in the longer term.37 Therefore, we used 6 months or longer outcomes for meta-analyses. Abstinence could be assessed by self-report or with biochemical verification.

Two studies44,45 used a factorial design to compare pharmacological and behavioral interventions; these comparisons were treated as separate studies in the analyses. We evaluated heterogeneity visually and with the Cochran Q statistic46 using a threshold p-value of less than 0.10^47^ and the I^2^ statistic.48 We considered I^2^ statistic thresholds of 0% to 40%, 30% to 60%, 50% to 90%, and 75% to 100% to represent between-study heterogeneity that might not be important, moderate, substantial, or considerable, respectively.49 We planned a priori to conduct subgroup analyses by depression status (severity and specific diagnosis), gender, and treatment sequencing, but there were not sufficient studies to conduct these analyses. All analyses were performed using Review Manager 5.0 software (The Cochrane Collaboration, Oxford).

### Grading the Evidence for Each Key Question

We graded the strength of evidence for each key question using the principles from the GRADE Working Group.50 In brief, this approach assesses the strength of evidence for each critical outcome by considering risk of bias, consistency, directness, precision, and publication bias. Other domains relevant to observational designs were not pertinent to our review. After considering each domain, a summary rating of High, Moderate, Low, or Insufficient strength of evidence was assigned after discussion by two reviewers (Table 2).

Table 2 Definitions for Strength of Evidence Rating

Strength of evidence rating | Definition
High quality | Further research is very unlikely to change our confidence in the estimate of effect
Moderate quality | Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate
Low quality | Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate
Insufficient | Evidence on an outcome is absent or too weak, sparse or inconsistent to estimate an effect

## PEER REVIEW

Peer reviewer comments and our responses are presented in Appendix B.