# INTRODUCTION

Tobacco smoking is the single greatest preventable cause of disease in the United States.1,2 Half of all American smokers who fail to quit will die of a smoking-related illness.3 Cigarette use is higher among Americans with depression than in the general U.S. population.4 Persons with depression are about twice as likely (45% versus 22%) to be current smokers than are individuals who are not depressed,5 and smokers are more likely to have a history of depression.6,7 Moreover, veterans have higher rates of depression and smoking compared to the general population.8–12

Several hypotheses have been offered to explicate the association between smoking and depression, including mood-enhancing effects of nicotine13,14 and common genetic and environmental factors. Depression also appears to be an important factor in smoking cessation.15–20 Smokers who are depressed are more likely to relapse from a quit attempt, have higher nicotine dependence, suffer negative mood symptoms from withdrawal, and suffer greater smoking-related morbidity and mortality than the general population of smokers.17,18,21–24

Smokers with depression are highly motivated to quit smoking.7,25 One study found that 79% of smokers with depression intended to quit, with 24% ready to make a quit attempt in the next month.26 Despite the complex relationship between tobacco use and depression, smokers with depression should be offered cessation services.27,28 Several evidence-based smoking cessation intervention strategies exist for the general population of smokers.29–35 All forms of nicotine replacement therapy (NRT) (e.g., gum, transdermal patch, inhaler, lozenges) augment successful quit attempts, increasing quit rates by as much as 50 to 70%.35 Also, use of some antidepressants (i.e., bupropion, nortriptyline) can double the chances of smoking cessation, and this effect seems independent of the antidepressive effects of these medications.36 For behavioral interventions, there is a strong dose-response relationship between treatment intensity and smoking cessation rates.37 More intensive interventions, measured by total contact time, are associated with increased abstinence rates. For example, smoking cessation counseling improves quit attempts over self-help aids and other less intensive therapies.29,33,34,38 Combining behavioral interventions with pharmacotherapy increases quit attempts over each therapy delivered alone and is considered the gold standard of care for effective smoking cessation treatment.29,37,39

Gender, depression status (e.g., history positive, depression symptom severity), and content delivery timing (i.e., sequential, concurrent) may differentially impact the effectiveness of smoking cessation intervention efforts for smokers with depression. When trying to quit smoking, women who are depressed may experience more difficulty with withdrawal symptoms and, consequently, higher rates of smoking relapse to alleviate withdrawal symptoms compared to their male smoker counterparts.40 Level of depressive symptoms or depression type may influence patients’ ability to make and maintain quit attempts.17,18,22 Also, smokers with depression may benefit from smoking cessation programs that target both depression symptoms and tobacco use. However, it is not known if these two conditions should be treated concurrently or sequentially. For example, it is not known if treating depression first influences smoking cessation treatment effectiveness. Treating depression first may lead to greater treatment adherence and, consequently, better cessation rates. It is plausible but unstudied. Smokers with psychiatric comorbidities may benefit from combined behavioral counseling and pharmacotherapy with longer therapeutic smoking cessation approaches (i.e., exceeding 8 to 12 weeks) to reduce likelihood of dropout and depression relapse.27,41 However, no systematic reviews have synthesized the comparative effectiveness of smoking cessation strategies for persons with depressive symptoms. Many unanswered questions remain about how effective smoking cessation interventions are for adults with depression.