# FUTURE RESEARCH

While this review provides some evidence about smoking cessation strategies for patients with depression, more work is needed in this area. First, we found very little trial data on intervening with smokers who are currently depressed. Persons with depression are about twice as likely to be smokers than persons without depression.5 Moreover, smokers with depression may experience more challenges when trying to make and maintain a quit attempt, such as greater negative mood symptoms from withdrawal, higher nicotine dependence, and greater likelihood of relapse, than smokers without depression.17,18,21,22,24,81 Secondary analysis of existing smoking cessation trial data could advance our understanding of smoking cessation strategies for patients with depression. Future studies should be designed to test smoking cessation interventions for this vulnerable population. Next, within the trials we identified, we found little research on key moderators that may influence treatment effectiveness (e.g., gender, depression status). Moderator analysis will facilitate subgroup identification, which may lead to better treatment matching.6

Evidence is growing that combination pharmacotherapy is effective for the general population of smokers.82 In 2009, the VA Pharmacy Benefits Management (PBM) Services released recommendations for the use of combination pharmacotherapy for tobacco use cessation. The VA PBM recommends combination NRT that involves the use of a longer acting NRT such as the patch in conjunction with a short-acting NRT (e.g., gum, inhaler, nasal spray) (http://www.pbm.va.gov). Future studies should be designed to allow for direct comparisons between combinations of likely efficacious NRT therapies for smokers with depression. Also, it is not known how to combine depression and smoking pharmacotherapies. Take, for example, a patient with depression who is improving on sertraline but wants to stop smoking. Should the provider add bupropion or change from sertraline to bupropion, which may risk worsening of depression? Future trials should investigate combination smoking cessation and depression pharmacotherapy among smokers with depression.

Behavioral counseling plus pharmacotherapy is considered the gold standard of care for effective smoking cessation interventions.29,37,39 Smokers with psychiatric comorbidities may benefit from combined behavioral counseling and pharmacotherapy with longer therapeutic approaches (i.e., exceeding 8 to 12 weeks) to reduce likelihood of dropout and depression relapse.41 Thus, future research should be designed to optimize dose, duration, and frequency of both behavioral counseling and pharmacotherapies. In addition, it is likely that patients with depression need strategies that target both depressive symptoms and smoking. Future research should seek to answer questions about the optimal sequencing of depression and smoking treatment content of smoking cessation interventions. Moreover, we were unable to tease apart the active components of individual therapies. Thus, important issues, such as mode of therapy (e.g., individual, group, telephone) and key therapeutic components (e.g., goal setting, monitoring of thoughts and moods, social support), cannot be answered by this systematic review. Future studies should be designed to disentangle active ingredients of behavioral counseling and the effects of delivery channels. Beyond scanning the reports included in this review, no attempt was made to synthesize information about adverse effects from observational studies and other data sources. Future research should be conducted to characterize adverse effects of treatment, including changes in negative affect and depressive symptoms.