# DISCUSSION

## SUMMARY AND DISCUSSION

There is a synergistic and potentially bidirectional relationship between depression and smoking.6,14,19,65,66 Smokers with depression are significantly less likely to quit smoking, and depressed individuals are more likely to be smokers.5–7 Consequently, there is a need to identify effective smoking cessation interventions for this disproportionately affected population. We conducted a systematic review of smoking cessation intervention strategies for persons with depression. We also sought to examine differential effects of smoking cessation treatment by depression status, gender, and treatment sequencing and to characterize adverse effects of smoking cessation treatments in patients with depression. We found insufficient evidence to examine moderator effects and to characterize adverse effects. However, findings suggest several promising smoking cessation strategies for persons with depression. We summarize and discuss our findings here.

We identified three types of intervention strategies: cotreatments augmented with behavioral mood management treatment (six trials), cotreatments augmented with antidepressant therapy (five trials), and cotreatments augmented with NRT (four trials). Cotreatments generally consisted of some type of smoking cessation counseling (e.g., brief, behavioral), with or without NRT. We also identified three additional trials that used behavioral counseling to promote exercise plus NRT,67 mailed self-help materials,51 or long-acting opiate antagonists plus behavioral counseling63 as smoking cessation interventions. Overall, we found insufficient evidence to support exercise behavioral counseling, mailed self-help materials, or naltrexone as smoking cessation strategies for smokers with depression. Although both naltrexone and mailed self-help materials showed positive effects in single trials, further study is required to assess the efficacy of these strategies. Also, it is possible that we may have missed studies with unpublished but relevant data.

We did not identify any studies using varenicline that met our eligibility criteria. Varenicline stimulates dopamine release, which reduces nicotine cravings and withdrawal symptoms, and blocks nicotine receptors, which may reduce the pleasurable effects of continued nicotine usage. Pooled results of two RCTs showed significantly higher abstinence rates at the end of 12 weeks of varenicline treatment compared to both placebo and bupropion.68,69 However, given the latest concerns about mental health instability within the veteran population,70 varenicline should be reserved for special cases and will require close observation.

Smokers with depression are more likely to have increased levels of negative mood both precessation and postcessation.15,71–73 Also, negative mood is associated with greater relapse rates.74,75 Mood management therapy may serve to moderate negative mood associated with making and maintaining a quit attempt.74 Therefore, smokers with depression may respond better to smoking cessation interventions augmented with mood management techniques. Our results support this hypothesis. Pooled results from our meta-analysis demonstrate a small, positive effect of adding behavioral mood management therapy to smoking cessation cotreatments. The number needed to treat with mood management therapy plus NRT or antidepressants is 12 persons to get 1 additional person to quit smoking for at least 6 months. The strength of evidence is moderate. Only six identified trials provided enough detail to assess cessation rates among smokers with depression. Moreover, we found significant heterogeneity in intensity of mood management therapy across studies, which may influence estimates of effectiveness.

All of the included antidepressant trials showed small, positive effects on smoking cessation, but a summary estimate of effect was not statistically significant. However, the strength of evidence for the lack of benefit for antidepressants as a smoking cessation aid for smokers with depression is low. Sample sizes were small and the number achieving cessation few, which limits precision of estimates of effects and our ability to detect statistically significant differences. Also, we were able to include only five trials, of which there was significant heterogeneity in antidepressant type. Only bupropion and nortriptyline have proven efficacy as smoking cessation pharmacotherapies.36,76 Meta-analysis results show little smoking cessation benefit for selective serotonin reuptake inhibitors such as sertraline and fluoxetine in the general population of smokers.36 Because results may differ by pharmacotherapy used, caution should be taken in applying our findings to other antidepressants that may be used to aid smokers with depression in quitting smoking.

Offering NRT to smokers with depression appears to have a small, positive effect on smoking cessation rates among depressed smokers. Cessation rates ranged from 14 to 22% in the three included studies that reported outcomes of 12 months or longer.44,57,64 These cessation rates are higher than the 3 to 5% of smokers who successfully maintain quit attempts a year later without treatment aids77 and are comparable to NRT quit rates in the general population of smokers.35 Yet, long-term cessation rates were lower for patients with current depressive symptoms57 than for those who are history positive for MDD44 (14% versus 22%, respectively). Smokers with current depressive symptoms may have greater difficulty quitting due to more issues with nicotine withdrawal or worsening of depressive symptoms during a quit attempt.78 Smokers with current depressive symptoms may need additional support to make and maintain a quit attempt. The strength of evidence for NRT use among smokers with depression is moderate. Data were sparse; we were able to include only four trials. However, studies were of good quality and reported consistent results.

## STRENGTHS AND LIMITATIONS

Our systematic review has a number of strengths that are consistent with the QUORUM reporting statement and the AMSTAR quality assessment of systematic reviews. These include a protocol-driven approach, a comprehensive literature search of multiple electronic databases, double data abstraction, quality assessment of the primary studies, and appropriate methods for combining estimates of effect. Despite these strengths, our review has several limitations.

Foremost is that few RCTs exist that test smoking cessation interventions among smokers with depression. The paucity of literature has important implications for this evidence review. First, in order to make meaningful comparisons, we created broad intervention categories that used different types of counseling modes (e.g., group, individual) and pharmacotherapies. Within each category, there is considerable heterogeneity. For example, we identified few medication trials and fewer with the same type of medication. Ideally, we would have wanted to analyze trials by specific medications since treatment effects may vary within broad classes of medications.

Second, few trials recruited smokers with current depression. In fact, many trials excluded patients with current or recent histories of depression. Therefore, many reports based classifications of depression on self-reported screening criteria (e.g., CES-D, BDI) for significant depressive symptoms. Self-report scales may be measures of general emotional distress or negative affect rather than specific depressive symptoms. In primary care settings, a positive depression screen has a positive predictive value of ≤ 50% for MDD.79 Thus, our review contains heterogeneity among the group of subjects included in trials classified as depressed. To address this heterogeneity, our protocol specified a stratified analysis by type of depression (e.g., history of MDD, current depressive symptoms, current MDD), but there were too few trials in any intervention category to follow this planned approach. Also, time since last episode, chronicity of depression, and other important variations in depressive disorders may be associated with outcomes. For example, some evidence supports that those with recurrent MDD compared to a single episode have worse outcomes6 and may differentially respond to certain interventions that target their depressive symptoms during a quit attempt. Our review is unable to address this issue. Moreover, most studies included in this report excluded participants with comorbid alcohol or substance abuse. Results are likely not generalizable to groups with these comorbidities.

In many instances, we examined subgroup data for this evidence review. Including studies that reported on subgroups of individuals with depression has limitations. By doing so, we introduce the possibility of false-negative studies because many of these studies were not powered to detect clinically important treatment effects in depressed subgroups. Meta-analysis helps to address this limitation, but with relatively few studies of small sample sizes, our analyses may remain underpowered. In addition, subgroup analyses, unless specified a priori and part of a limited number of subgroups evaluated, may produce false-positive or spurious results.80

Data were limited on the majority of our key questions. No studies tested differential effects of smoking cessation interventions by treatment sequencing among smokers with depression. Literature on treatment differences by gender and depression status was also sparse. Our results on adverse effects are limited as well. Ideally, we would have conducted a separate search for adverse effects in the observational literature. However, it is unlikely that much literature exists on these types of interventions specific to our population of interest—smokers with a history of depression or with current depression. Lastly, few of the trials in this evidence review included VA users. Although veterans have higher rates of depression and smoking compared to the general population,8–12 results should be generalizable to the VA population.

## CONCLUSIONS

We identified only 16 trials, encompassing 1756 smokers with depression. Just three of these trials actively recruited participants with elevated depressive symptoms.57,58,67 Most patients included in this review were history positive for depression; findings best apply to this population. For patients with current depression, we have little data. We were able to conduct meta-analyses of only two contrasts: (1) addition of any type of antidepressant and (2) treatment augmented by behavioral mood management counseling. Results of this systematic review indicate promising smoking cessation strategies for smokers with depression.

Table 11 summarizes the strength of evidence for each of our key questions and contrasts. Our results support a small, positive effect for adding mood management counseling for smoking cessation among patients with depression. However, it is uncertain if the effects of mood management counseling may differ by therapy mode (individual versus group therapy). We did not find adequate support for adding antidepressants; we may be underpowered to detect statistically significant differences. Evidence suggests support for adding NRT; however, included trials were too varied to be analyzed quantitatively. While most trials included in this evidence review were of good quality and had consistent results, data were sparse. We expect that future research will likely have an important impact on our confidence in the estimates of effectiveness of smoking cessation treatments for smokers with depression. However, evidence suggests that depression does not need to be resolved before tobacco cessation treatment is initiated. Smokers with depression can successfully maintain smoking cessation. To improve the likelihood of success, health care providers should consider encouraging their depressed patients who smoke to seek smoking cessation services that include behavioral mood management treatment and NRT.

Table 11 Summary of the Strength of Evidence for Key Questions 1 to 5

Number of studies (subjects)^a^ | Domains pertaining to strength of evidence | | | | Magnitude of effect and strength of evidence
| Risk of Bias: Design/ Quality | Consistency | Directness | Precision | Percentage abstinent from smoking at least 6 months postrandomization or relative risk ratio
Key Question 1: NRT | | | | | Moderate SOE
Moderate SOE | 4 (699) RCT/Good | Consistent | Direct | Imprecise | 14 to 22%
Key Question 1: Antidepressant therapy | | | | | Low SOE
5 (484) | RCT/Good | Consistent | Direct | Imprecise | 1.48 (95% CI 0.86 to 2.54)^b^
Key Question 1: Mood management treatment | | | | | Moderate SOE
6 (466) | RCT/Good | Consistent | Direct | Imprecise | 1.45 (95% CI 1.01 to 2.07)^c^
Key Question 1: Other intervention strategies | | | | | Low SOE
3 (202) | RCT/Fair | Inconsistent | Direct | Imprecise | 17 to 39%
Key Question 2: Differential effects by depression status | | | | | Insufficient SOE
2 (305) | RCT/Good | Inconsistent | Direct | Imprecise | 18 to 39%
Key Question 3: Differential effects by gender | | | | | Insufficient SOE
1 (36) | RCT/Good | Consistent | Direct | Imprecise | 22%
Key Question 4: Differential effects by treatments delivered concurrently or sequentially | | | | | Insufficient SOE
0 (0) | --- | --- | --- | --- | ---
Key Question 5: Adverse effects | | | | | Insufficient SOE
5 (1,652) | RCT/Good | Inconsistent | Indirect | Imprecise

a Numbers reflect participants with depression only for KQs 1 to 4 and all study participants for KQ 5.

b Magnitude of effect calculated from 3 trials included in meta-analysis (n = 255).

c Magnitude of effect calculated from 5 trials included in meta-analysis (n = 402).

Abbreviations: CI = confidence interval, RCT = randomized controlled trial, SOE = strength of evidence