# ACRONYMS AND ABBREVIATIONS

AE: adverse effects
am: ante meridian (before noon)
BA: behavioral activation
BATS: behavioral activation treatment for smoking
BID: two times per day
BDI-II: Beck Depression Inventory-II
CBT: cognitive behavioral therapy
CES-D: Center for Epidemiologic Studies-Depression
CI: confidence interval
CO: carbon monoxide
DIS: Diagnostic Interview Schedule
FTQ: Fagerstrom Tolerance Questionnaire
FTND: Fagerstrom Test for Nicotine Dependence
GEE: generalized estimating equation
ID: identification
HDRS: Hamilton Depression Rating Scale
ITT: intention to treat
MDD: major depressive disorder
MDE: major depressive episode
mg: milligram or milligrams
mo: month or months
ml: milliliter or milliliters
N or n: number
NA: not applicable
NCI: National Cancer Institute
ng: nanogram
NRT: nicotine replacement therapy
NR: not reported
ns or NS: not significant
OR: odds ratio
p: probability
pm: post meridian (after noon)
POMS: Profile of Mood States
ppm: parts per million
RCT: randomized controlled trial
SCID: Structured Clinical Interview for DSM Diagnoses
SD: standard deviation
SE: standard error
ST: standard treatment
UDD: unipolar depressive disorder
vs: versus
wk: week or weeks
yr: year or years