# EXCLUDED STUDIES

All studies listed in Table 12 were reviewed in their full-text version and excluded for the reason indicated. An alphabetical reference list follows the table.

Table 12 List of Excluded Studies

Reference | Population not depressed | Main outcome not of interest to key questions | Not peer-reviewed | Main outcome not reported at desired interval | Not RCT or secondary analysis | Analysis does not address key questions
Acton, 2005 (203) | X
Alderton, 2009 (5) | | | | | X
Barnett, 2008 (82) | | X
Bercaw, 2008 (963) | | | X
Berlin, 2006 (141) | | | | X
Blondal, 1999 (1317) | | | | | | X
Brown, 2007 (117) | X
Buchanan, 2004 (1247) | X
Capone, 2003 (968) | | | X
Carmody, 2008 (567) | X
Carton, 2002 (300) | X
Catley, 2003 (278) | X
Catley, 2005 (179) | X
Collins, 2003 (1265) | | | X
Cornelius, 1997 (1036) | | X
Covey, 2008 (1204) | X
Covey, 1990 (445) | | | | X
Cox, 2004 (237) | | X
Csonka, 2008 (1206) | | | X
Dalack, 1995 (413) | | X
Frederick, 1996 (924) | | X
Friend, 2007 (123) | X
Gilbert, 1999 (366) | | X
Ginsberg, 1995 (1086) | | X
Ginsberg, 1997 (381) | | X
Glassman, 1993 (425) | X
Glassman, 2001 (325) | | X
Glassman, 1988 (451) | | | | X
Haas, 2005 (235) | | | | | | X
Hayford, 1997 (1325) | | | X
Helgason, 2004 (742) | | | | | X
Hernandez-Reif, 1999 (369) | X
Hill, 2007 (626) | | | | | X
Hitsman, 1999 (363) | X
Jarvik, 2000 (1297) | X
Keuthen, 2000 (343) | X
Killen, 1999 (1035) | X
Killen, 2008 (1197) | X | | | | | X
Lerman, 2004A (1256) | X
Lerman, 2004 B(215) | | X
Leventhal, 2008 (85) | X
Levine, 2000 (1152) | | | X | | X
McCarthy, 2008 (587) | X
McClure, 2009 (34) | | | | | | X
McFall, 2005 (1240) | X
McHugh, 2001 (1291) | X
Mermelstein, 2003 (788) | X
Munoz, 2006 (165) | | | | | | X
Oncken, 2007 (641) | X
Patten, 2002 (304) | | | | X
Patten, 1998 (375) | X
Perkins, 2008 (1199) | | X
Piper, 2010 (1113) | X
Pomerleau, 2003 (2854) | | X
Prochaska, 2008 (115) | | X
Rabius, 2008 (42) | X
Rovina, 2007 (604) | | | | | X
Schippers, 2006 (1233) | | | | X
Smith, 2003 (276) | X
Sonne, 2010 (465) | X
Spring, 2007A(133) | | | | X
Spring, 2004(1255)
Spring, 2007B (150) | | | | | X
Strong, 2009 (8) | X
Swan, 2003 (772) | X
Thorndike, 2008 (91) | X
Thorndike, 2006 (1228) | X
Trockel, 2008 (53) | X
Uyar, 2007 (607) | X
Vazquez, 1999 (357) | | | | | X
Walsh, 2008 (74) | X
Wetter, 1999 (884) | X
Wileyto, 2005 (189) | | X
Zelman, 1992 (946) | X
Ziedonis, 1997 (1328) | X

## LIST OF EXCLUDED STUDIES

Acton GS, Kunz JD, Wilson M, et al. The construct of internalization: conceptualization, measurement, and prediction of smoking treatment outcome. Psychol Med. 2005;35(3):395-408. [pmid: 15841875].
Alderton W, Karran E, Ward S. Current and Future Perspectives in Psychiatric Drug Discovery. Drug News Perspect. 2009;22(6):360-4. [pmid: 19771325].
Barnett PG, Wong W, Hall S. The cost-effectiveness of a smoking cessation program for out-patients in treatment for depression. Addiction. 2008;103(5):834-40. [pmid: 18412763].
Bercaw EL. A behavioral activation approach to smoking cessation for depressed smokers at veterans affairs medical centers. ProQuest Information & Learning. 2008.
Berlin I, Covey LS. Pre-cessation depressive mood predicts failure to quit smoking: the role of coping and personality traits. Addiction. 2006;101(12):1814-21. [pmid: 17156181].
Blondal T, Gudmundsson LJ, Tomasson K, et al. The effects of fluoxetine combined with nicotine inhalers in smoking cessation--a randomized trial. Addiction (Abingdon, England). 1999;(7):1007-15.
Brown RA, Niaura R, Lloyd-Richardson EE, et al. Bupropion and cognitive-behavioral treatment for depression in smoking cessation. Nicotine Tob Res. 2007;9(7):721-30. [pmid: 17577801].
Buchanan LM, El-Banna M, White A, et al. An exploratory study of multicomponent treatment intervention for tobacco dependency. Journal of nursing scholarship : an official publication of Sigma Theta Tau International Honor Society of Nursing/Sigma Theta Tau. 2004;(4):324-30.
Capone D-AL. An emotion-focused problem-solving smoking cessation intervention for depression-prone college students. ProQuest Information & Learning. 2003.
Carmody TP, Duncan C, Simon JA, et al. Hypnosis for smoking cessation: A randomized trial. Nicotine Tob Res. 2008;10(5):811-818. [pmid: 18569754].
Carton S, Le Houezec J, Lagrue G, et al. Early emotional disturbances during nicotine patch therapy in subjects with and without a history of depression. J Affect Disord. 2002;72(2):195-9. [pmid: 12200210].
Catley D, Ahluwalia JS, Resnicow K, et al. Depressive symptoms and smoking cessation among inner-city African Americans using the nicotine patch. Nicotine Tob Res. 2003;5(1):61-8. [pmid: 12745507].
Catley D, Harris KJ, Okuyemi KS, et al. The influence of depressive symptoms on smoking cessation among African Americans in a randomized trial of bupropion. Nicotine Tob Res. 2005;7(6):859-70. [pmid: 16298721].
Collins BN, Niaura R, Wileyto EP, et al. Effect of bupropion on depression symptoms in highly dependent smokers. Society for Research on Nicotine and Tobacco 9th Annual Meeting. February 19–22. New Orleans, LA. 2003:98.
Cornelius JR, Salloum Ihsan M, Ehler JG, et al. Double-blind fluoxetine in depressed alcoholic smokers. Psychopharmacol Bull. 1997;33(1):165-170. [pmid: 9133770].
Covey LS, Botello-Harbaum M, Glassman AH, et al. Smokers’ response to combination bupropion, nicotine patch, and counseling treatment by race/ethnicity. Ethn Dis. 2008(1):59-64. [pmid: 18447101].
Covey LS, Glassman AH, Stetner F. Depression and depressive symptoms in smoking cessation. Compr Psychiatry. 1990;31(4):350-4. [pmid: 2387147].
Cox LS, Patten CA, Niaura RS, et al. Efficacy of bupropion for relapse prevention in smokers with and without a past history of major depression. J Gen Intern Med. 2004;19(8):828-34. [pmid: 15242467].
Csonka A, Jonas Z. The combination of targeted cognitive-behavioural psychotherapy and pharmacotherapy for patients suffering from depression in smoking cessation. International Journal of Neuropsychopharmacology. 2008(Suppl 1):92.
Dalack GW, Glassman AH, Rivelli S, et al. Mood, major depression, and fluoxetine response in cigarette smokers. Am J Psychiatry. 1995;152(3):398-403. [pmid: 7864266].
Frederick SL, Humfleet GL, Hall SM, et al. Sex differences in the relation of mood to weight gain after quitting smoking. Experimental and Clinical Psychopharmacology. 1996;4(2):178-185.
Friend KB, Pagano ME. Timevarying predictors of smoking cessation among individuals in treatment for alcohol abuse and dependence: findings from Project MATCH. Alcohol Alcohol. 2007;42(3):234-40. [pmid: 17526633].
Gilbert DG, Crauthers DM, Mooney DK, et al. Effects of monetary contingencies on smoking relapse: influences of trait depression, personality, and habitual nicotine intake. Exp Clin Psychopharmacol. 1999;7(2):174-81. [pmid: 10340157].
Ginsberg D, Hall SM, Reus VI, et al. Mood and depression diagnosis in smoking cessation. Experimental and Clinical Psychopharmacology. 1995;3(4):389-395.
Ginsberg JP, Klesges RC, Johnson KC, et al. The relationship between a history of depression and adherence to a multicomponent smoking-cessation program. Addict Behav. 1997;22(6):783-7. [pmid: 9426796].
Glassman AH, Covey LS, Dalack GW, et al. Smoking cessation, clonidine, and vulnerability to nicotine among dependent smokers. Clin Pharmacol Ther. 1993;54(6):670-9. [pmid: 8275622].
Glassman AH, Covey LS, Stetner F, et al. Smoking cessation and the course of major depression: a follow-up study. Lancet. 2001;357(9272):1929-32. [pmid: 11425414].
Glassman AH, Stetner F, Walsh BT, et al. Heavy smokers, smoking cessation, and clonidine. Results of a double-blind, randomized trial. JAMA. 1988;259(19):2863-6. [pmid: 3367452].
Haas AL, Munoz RF, Humfleet GL, et al. Influences of mood, depression history, and treatment modality on outcomes in smoking cessation. J Consult Clin Psychol. 2004;72(4):563-70. [pmid: 15301640].
Hayford KE, Patten CA, Rummans TA, et al. Effectiveness of Bupropion for Smoking Cessation for Smokers with a History of Major Depression CONFERENCE ABSTRACT. 150th Annual Meeting of the American Psychiatric Association. San Diego, California, USA. 17– 22 May, 1997. 1997.
Helgason AR, Tomson T, Lund KE, et al. Factors related to abstinence in a telephone helpline for smoking cessation. European Journal of Public Health. 2004;14(3):306-310. [pmid: 15369039].
Hernandez-Reif M, Field T, Hart S. Smoking cravings are reduced by self-massage. Prev Med. 1999;28(1):28-32. [pmid: 9973585].
Hill KP, Chang G. Cognitive behavioral therapy and nicotine replacement for smoking cessation in psychiatric outpatients with major depression. Addictive Disorders and their Treatment. 2007;6(2):67-72.
Hitsman B, Pingitore R, Spring B, et al. Antidepressant pharmacotherapy helps some cigarette smokers more than others. J Consult Clin Psychol. 1999;67(4):547-54. [pmid: 10450625].
Jarvik ME, Caskey NH, Wirshing WC, et al. Bromocriptine reduces cigarette smoking. Addiction (Abingdon, England). 2000;(8):1173-83.
Keuthen NJ, Niaura RS, Borrelli B, et al. Comorbidity, smoking behavior and treatment outcome. Psychother Psychosom. 2000;69(5):244-50. [pmid: 10965289].
Killen JD, Fortmann SP, Davis L, et al. Do heavy smokers benefit from higher dose nicotine patch therapy?. Experimental and Clinical Psychopharmacology. 1999;7(3):226-233. [pmid: 10472510].
Killen JD, Fortmann SP, Schatzberg AF, et al. Extended cognitive behavior therapy for cigarette smoking cessation. Addiction (Abingdon, England). 2008;(8):1381-90.
Lerman C, Kaufmann V, Rukstalis M, et al. Individualizing nicotine replacement therapy for the treatment of tobacco dependence: a randomized trial. Ann Intern Med. 2004:426-33. (A). [pmid: 15023708].
Lerman C, Niaura R, Collins BN, et al. Effect of bupropion on depression symptoms in a smoking cessation clinical trial. Psychol Addict Behav. 2004;18(4):362-6. (B). [pmid: 15631608].
Leventhal AM, Ramsey SE, Brown RA, et al. Dimensions of depressive symptoms and smoking cessation. Nicotine Tob Res. 2008;10(3):507-17. [pmid: 18324570].
Levine MD. The effect of depression history on smoking cessation in weight-concerned women. ProQuest Information & Learning. 2000.
McCarthy DE, Piasecki TM, Lawrence DL, et al. A randomized controlled clinical trial of bupropion SR and individual smoking cessation counseling. Nicotine Tob Res. 2008;10(4):717-729. [pmid: 18418793].
McClure JB, Swan GE, Jack L, et al. Mood, side-effects and smoking outcomes among persons with and without probable lifetime depression taking varenicline. J Gen Intern Med. 2009;24(5):563-9. [pmid: 19238488].
McFall M, Saxon AJ, Thompson CE, et al. Improving the rates of quitting smoking for veterans with posttraumatic stress disorder. The American Journal of Psychiatry. 2005(7):1311-9. [pmid: 15994714].
McHugh F, Lindsay GM, Hanlon P, et al. Nurse led shared care for patients on the waiting list for coronary artery bypass surgery: a randomised controlled trial. Heart (British Cardiac Society). 2001;(3):317-23. [pmid: 11514487].
Mermelstein R, Hedeker D, Wong SC. Extended telephone counseling for smoking cessation: Does content matter?. J Consult Clin Psychol. 2003;71(3):565-574. [pmid: 12795579].
Munoz RF, Lenert LL, Delucchi K, et al. Toward evidence-based Internet interventions: A Spanish/English Web site for international smoking cessation trials. Nicotine Tob Res. 2006;8(1):77-87. [pmid: 16497602].
Oncken C, Cooney J, Feinn R, et al. Transdermal nicotine for smoking cessation in postmenopausal women. Addict Behav. 2007;32(2):296-309. [pmid: 16765526].
Patten CA, Drews AA, Myers MG, et al. Effect of depressive symptoms on smoking abstinence and treatment adherence among smokers with a history of alcohol dependence. Psychol Addict Behav. 2002;16(2):135-42. [pmid: 12079252].
Patten CA, Martin JE, Myers MG, et al. Effectiveness of cognitive-behavioral therapy for smokers with histories of alcohol dependence and depression. J Stud Alcohol. 1998;59(3):327-35. [pmid: 9598714].
Perkins KA, Ciccocioppo M, Conklin CA, et al. Mood influences on acute smoking responses are independent of nicotine intake and dose expectancy. J Abnorm Psychol. 2008(1):79-93. [pmid: 18266487].
Piper ME, Smith SS, Schlam TR, et al. Psychiatric disorders in smokers seeking treatment for tobacco dependence: Relations with tobacco dependence and cessation. J Consult Clin Psychol. 2010;78(1):13-23. [pmid: 20099946].
Pomerleau OF, Pomerleau CS, Marks JL, et al. Prolonged nicotine patch use in quitters with past abstinence-induced depressed mood. J Subst Abuse Treat. 2003;24(1):13-8. [pmid: 12646326].
Prochaska JJ, Hall SM, Tsoh JY, et al. Treating tobacco dependence in clinically depressed smokers: effect of smoking cessation on mental health functioning. Am J Public Health. 2008;98(3):446-8. [pmid: 17600251].
Rabius V, Pike KJ, Wiatrek D, et al. Comparing internet assistance for smoking cessation: 13-month follow-up of a six-arm randomized controlled trial. J Med Internet Res. 2008;10(5):e45. [pmid: 19033146].
Rovina N, Nikoloutsou I, Dima E, et al. Smoking cessation treatment in a real-life setting: The Greek experience. Therapeutic Advances in Respiratory Disease. 2007;1(2):93-104. [pmid: 19124351].
Schippers G, Van der Meer R, Willemsen M, et al. Preliminary results from a RCT of a smoking cessation intervention for smokers with a history of major depression. Eur Neuropsychopharmacol. 2006:S201.
Smith SS, Jorenby DE, Leischow SJ, et al. Targeting smokers at increased risk for relapse: treating women and those with a history of depression. Nicotine Tob Res. 2003;5(1):99-109. [pmid: 12745511].
Sonne SC, Nunes EV, Jiang H, et al. The relationship between depression and smoking cessation outcomes in treatment-seeking substance abusers. Am J Addict. 2010;19(2):111-118. [pmid: 20163382].
Spring B, Doran N, Pagoto S, et al. Fluoxetine, smoking, and history of major depression: A randomized controlled trial. J Consult Clin Psychol. 2007;75(1):85-94. (A). [pmid: 17295567].
Spring B, Hines E. Fluoxetine as a quit smoking aid for depression-prone smokers. ClinicalTrials.gov. Available at: www.clinicaltrials.gov. 2004.
Spring B, Hitsman B, Pingitore R, et al. Effect of tryptophan depletion on smokers and nonsmokers with and without history of major depression. Biol Psychiatry. 2007;61(1):70-7. (B). [pmid: 16893526].
Strong DR, Kahler CW, Leventhal AM, et al. Impact of bupropion and cognitive-behavioral treatment for depression on positive affect, negative affect, and urges to smoke during cessation treatment. Nicotine Tob Res. 2009;11(10):1142-53. [pmid: 19574407].
Swan GE, Jack LM, Curry S, et al. Bupropion SR and counseling for smoking cessation in actual practice: Predictors of outcome. Nicotine Tob Res. 2003;5(6):911-921. [pmid: 14668075].
Thorndike AN, Regan S, McKool K, et al. Depressive symptoms and smoking cessation after hospitalization for cardiovascular disease. Arch Intern Med. 2008;168(2):186-91. [pmid: 18227366].
Thorndike FP, Friedman-Wheeler DG, Haaga DA. Effect of cognitive behavior therapy on smokers’ compensatory coping skills. Addict Behav. 2006(9):1705-10. [pmid: 16427745].
Trockel M, Burg M, Jaffe A, et al. Smoking behavior postmyocardial infarction among EN-RICHD trial participants: cognitive behavior therapy intervention for depression and low perceived social support compared with care as usual. Psychosom Med. 2008;70(8):875-82. [pmid: 18842753].
Uyar M, Filiz A, Bayram N, et al. A randomized trial of smoking cessation. Medication versus motivation. Saudi Medical Journal. 2007;28(6):922-926. [pmid: 17530112].
Vazquez FL, Becona E. Depression and smoking in a smoking cessation programme. J Affect Disord. 1999;55(2–3):125-32. [pmid: 10628881].
Walsh Z, Epstein A, Munisamy G, et al. The impact of depressive symptoms on the efficacy of naltrexone in smoking cessation. J Addict Dis. 2008;27(1):65-72. [pmid: 18551889].
Wetter DW, Fiore MC, Jorenby DE, et al. Gender differences in smoking cessation. J Consult Clin Psychol. 1999;67(4):555-562. [pmid: 10450626].
Wileyto EP, Patterson F, Niaura R, et al. Recurrent event analysis of lapse and recovery in a smoking cessation clinical trial using bupropion. Nicotine Tob Res. 2005;7(2):257-68. [pmid: 16036283].
Zelman DC, Brandon TH, Jorenby DE, et al. Measures of affect and nicotine dependence predict differential response to smoking cessation treatments. J Consult Clin Psychol. 1992;60(6):943-952. [pmid: 1460156].
Ziedonis D, Harris P, Brandt P, et al. Motivational enhancement therapy and nicotine replacement improve smoking cessation outcomes for smokers with schizophrenia or depression. Addiction. 1997;633.