# EVIDENCE TABLES

Comparative Effectiveness of Smoking Cessation Treatments for Patients With Depression

Study Information | Interventions | | Participant Characteristics | | | Results and Adverse Effects | | | | | Comments/Quality Scoring
Study ID: Brown, Kahler, Niaura, et al., 2001
Geographical location: Providence, RI Recruitment: Advertisement; newspaper Setting:; - Mixed; - Academic; Veterans clinics: No Study design: RCT Number of participants enrolled: 179 Duration of follow-up: End of treatment, 1, 6, 12 mo follow-up [underlined: Methods of assessment] Smoking status: 7 day point previous CO monitor Depression status: BDI POMS | Intervention description: Standard CBT for smoking cessation (ST) vs ST + CBT for depression (CBT-D) ST = 93 CBT = 86 Patients randomized to treatment condition according to gender, current depressive symptoms (BDI = 9), and level of nicotine dependence Smoking cessation intervention: [underlined: Behavioral interventions] Eight 2-hr group CBT sessions in 6 wk (2 sessions clustered around quit date) colead by two therapists (clinical psychologist postdoctoral fellows, interns in clinical psychologist, clinical psychologists) Key components of smoking cessation therapy included treatment rationale, self-monitoring, self-management, nicotine fading, relapse prevention, social support [underlined: Drugs:] None Depression intervention: [underlined: Behavioral interventions] Eight 2-hour group CBT sessions in 6 wk (2 sessions clustered around quit date) colead by two therapists (clinical psych post- doctoral fellows, interns in clinical psych, clinical psychologists) [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Eight 2-hour group smoking cessation only CBT sessions in 6 wk (2 sessions clustered around quit date) colead by two therapists (clinical psych postdoctoral fellows, interns in clinical psych, clinical psychologists) [underlined: Drugs:] None Depression intervention: None Mean contact time/proportion of sessions completed: Sessions attended out of 8 possible:; - Control 5.8 of 8 = 72.5%; - Intervention 5.9 of 8 = 73.7%; Treatment sequencing: Not done | | Inclusion criteria:; - Ages 18 to 70; - Smoked for at least 1 yr (10 cigarettes/day); - History of MDD; Exclusion criteria:; - Current depression; - Substance use; - Current weekly psychotherapy; - Use of other tobacco products; - Intent to use pharmacological aid for cessation; - Psychotropic therapy; Age: Mean (SD): 45.1 (9.27) Gender (n [%]): Female 107 (59.8%) Race/ethnicity (n [%]): White 174 (97.2%) Baseline depression assessment:; - SCID; - BDI (cutoff ≥ 9); - Mean (SD) = 7.8 (6.31); Smoking characteristics:; - FTND = 6.8 (1.93); - Saliva cotinine = 383.7 ng/ml (170.59); Comorbid conditions (n [%]):; - History of alcohol abuse 78 (43.6%); - History of drug abuse 60 (35.8%) | | | Follow-up rate: 6 mo = 91% 12 mo = 92% Important baseline differences: None Outcomes of interest 1) Abstinence rate: | | | | | General comments: None Applicability cautions: None Study-level quality assessment: Good Measure of smoking adequate? Yes Assessment of adverse effects adequate? No
| | | | | | | 6 mo | | 12 mo | | General comments: None Applicability cautions: None Study-level quality assessment: Good Measure of smoking adequate? Yes Assessment of adverse effects adequate? No
| | | | | | ST | 24.7 | | 24.7 | | General comments: None Applicability cautions: None Study-level quality assessment: Good Measure of smoking adequate? Yes Assessment of adverse effects adequate? No
| | | | | | CBT | 24.4 | | 32.5 | | General comments: None Applicability cautions: None Study-level quality assessment: Good Measure of smoking adequate? Yes Assessment of adverse effects adequate? No
| | | | | | 2) Medication adherence rate: NR 3) Differential effects by gender: NA 4) Differential effects by depression status: NA 5) Differential effects by treatment sequencing: NA Report adverse effects? No | | | | | General comments: None Applicability cautions: None Study-level quality assessment: Good Measure of smoking adequate? Yes Assessment of adverse effects adequate? No
Study ID: Covery, Glassman, and Stetner; 1999
Geographical location: New York, NY Recruitment: Advertisement Setting:; - Mental health clinic; - Academic; Veterans clinics: No Study design: RCT Number of participants enrolled: 80 randomized 68 completed 52 data at 6 mo follow-up Duration of follow-up: 6 mo phone follow-up post end of 1 mo treatment [underlined: Methods of assessment] Smoking status:; - 7 day abstinence self-report; - Blood cotinine concentration < 15 ng/ml; Depression status: Score for Schedule for Affective Disorders indicating depression– NR | Intervention description: Study compared the added effectiveness of naltrexone to behavioral counseling (6 sessions) vs placebo treatment Behavioral counseling + Naltrexone (n = 40) vs behavioral counseling + placebo (n = 40) Smoking cessation intervention: [underlined: Behavioral interventions] 6 individual sessions based on the American Lung Association smoking cessation program (modified) conducted by trained therapist Topics consisted of fading, target quit date and coping skills for cravings and withdrawal symptoms Sessions held 3 and 5 days prior to quit date, then weekly x 1 mo [underlined: Drugs] Naltrexone, 25 mg/day 3 to 5 days prior to quit, increased to 50 mg/day on quit date, then increased to 75 mg/day if tolerated x 1 mo Depression intervention: None in addition to behavioral intervention [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Same 6 sessions as described above [underlined: Drugs] Placebo, 25, 50, then 75 mg/day x 1 mo Depression intervention: None, as above Mean contact time/proportion of sessions completed: 27 of 40 (67.5%) subjects in both arms completed the treatment; number of sessions attended NR Treatment sequencing: NA | | Inclusion criteria:; - Ages 18 to 65; - Smoked ≥ 20 cigarettes/day; - Smoked before leaving house when awakened; - Made at least 1 attempt to quit in the past; Exclusion criteria:; - Current or history of psychiatric disorder other than MDD; not clearly specified; - Current major medical illness; - Current MDD, substance abuse or psychotic disorder excluded; Age: Mean (SD): NR for whole sample Range 18 to 65 Gender (n [%]): N (65) NR for entire sample Female Naltrexone 20.4 of 30 (68%) Placebo 22.8 of 38 (60%) Race/ethnicity (n [%]): NR Baseline depression assessment:; - Schedule for Affective Disorders, Life-time version; - History of depression; Naltrexone 12.5 of 30, (42%) Placebo 20 of 38 (53%) Smoking characteristics: Mean (SD): Self-report usage:; - Naltrexone 34.3 (11.9) cigarettes/day; - Placebo 30.3 (10.1) cigarettes/day; Cotinine level:; - Naltrexone: 262 (130) ng/ml; - Placebo: 271 (110) ng/ml; Comorbid conditions (n [%]): History of major depression:; - Total 37 of 68 (55%); - Naltrexone 12.6 of 30 (42%); - Placebo 20 of 38 (53%) | | | Follow-up rate: NR Important baseline differences: Age p < .004 Naltrexone 39.7 (8.0) yr Placebo 33.8 (8.2) yr Naltrexone: 75% (30 of 40) patients started study, 25% dropped out prior to quit date Placebo: 95% (38 of 40) patients started study, 5% dropped out prior to quit date [underlined: Outcomes of interest] 3 mo NR for entire population 6 mo quit rate (n, %, OR, p) Naltrexone 30 (26.7) 1.9 ns Placebo 36 (15.2) 1) Abstinence rate: End of treatment (4 wk) Naltrexone 14 of 30 (46.7%) Placebo 10 of 38 (26.3%) OR 2.5, ns 2) Medication adherence rate: NR 3) Differential effects by gender: | | | | | General comments: Differential dropout prior to quit date:; - Naltrexone 10 of 40 (25%); - Placebo 2 of 40 (5%); Then differential dropout during study in the opposite direction:; - Naltrexone 3 of 30 (10%); - Placebo 11 of 38 (29%); reason given was that the pill was not helpful; Applicability cautions:; - Mean age < 40; - More than 60% female; Study-level quality assessment: Fair Comments:; - Poor description of exclusion criteria; - Poor description of depression measure; - Unequal dropout rate prior to quit date; - No ITT analysis with 25% dropout rate in one arm but only 5% in other; Measure of smoking adequate? Yes; cotinine Assessment of adverse effects adequate? Original study questionnaire
| | | | | | End of treatment (4 wk) | | | | OR
| | | | | | Women (44) | | | | 3.5
| | | | | | Men (22) | | | | 1.4
| | | | | | 6 mo quit rate:
| | | | | | | Nal | Pla | OR | p
| | | | | | Women | 27.8 | 7.4 | 4.6 | .07
| | | | | | 4) Differential effects by depression status: 4 wk OR only present or absent given Negative (32) 0.8 Positive (36) 8.4 6 mo quit rate:
| | | | | | | Nal | Pla | OR
| | | | | | Smokers | 28.6 | 9.1 | 4.0 ns
| | | | | | Within depressed (4 wk) Women (26) 4.4 Men (10) 2.7 6 mo quit rate:
| | | | | | | Nal | Pla | OR | p
| | | | | | Women | 22.2 | 0.0 | 3.4 | .04
| | | | | | 5) Differential effects by treatment sequencing: NA Report adverse effects? Yes; - 11 naltrexone dropout; - Minnesota Withdrawal Symptom Scale, 6 pt scale; side effects on original 3-point scale; - List; - Panic attack; - Malaise; - Sleeplessness; - Lack of concentration; - Nausea and vomiting; - Disorientation; - Tremors
Study ID: Covey, Glassman, Stetner, et al., 2002
Geographical location: New York, NY Recruitment: Advertisement Setting: NR Veterans clinics: No Study design: RCT Number of participants enrolled: 66 placebo 68 sertraline Duration of follow-up: 34 week post-randomization [underlined: Methods of assessment] Smoking status: Self-report for 7 days and serum cotinine < 25 ng/ml Depression status: 6 point unvalidated scale | Intervention description: 9-week double-blind trial of sertraline titrated to 200 mg daily (n = 68) vs placebo (n = 66) following 1 wk placebo run-in; both arms received behavioral intervention Smoking cessation intervention: [underlined: Behavioral interventions] Weekly 45-minute individual behavioral session that included standard smoking cessation techniques (orientation to health risk, benefits of cessation, coping skills for withdrawal symptoms and avoiding relapse) [underlined: Drugs] Sertraline 50 mg daily wk 1 100 mg daily wk 2 150 mg daily wk 3 200 mg daily wk 4–9 9 day medication taper Depression intervention: [underlined: Behavioral interventions] Smoking cessation intervention augmented with a supportive approach to manage negative affect [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Same as intervention [underlined: Drugs:] Placebo Depression intervention: [underlined: Behavioral interventions] Same as intervention Mean contact time/proportion of sessions completed: 9 visits during 12 wk intervention, each lasting about 45 min Treatment sequencing: NA | | Inclusion criteria:; - ≥1 MDE that remitted ≥ 6 mo prior to study; - Ages 18 to 70; - ≥ 20 cigarettes/day x ≥ 1 yr; - ≥ Prior quit attempt; - Decreased cigarettes by ≥ 50% on quit date; Exclusion criteria:; - Serious medical illness; - Psychotropic medication; - MDD; - Alcohol or drug dependence; - PTSD, panic disorder, bulimia, anorexia nervosa within past 6 mo; - Other lifetime major Axis I disorders; - Pregnancy; Age: Mean (SD): 44.5 (10.7) Gender (n [%]): Female 85 (63.4%) Race/ethnicity (n [%]): White 117 (87.3%) Baseline depression assessment: BDI-21 8.0 (7.7) CES-D 14.9 (10.8) HDRS 4.8 (4.4) Smoking characteristics: *; - Yr smoking: 25.4 (10.5), 26.6 (10.8); - Cigarettes/day: 29.6 (11.5), 26.9 (9.0); - FTND: 7.1 (2.4), 6.1 (2.4); * = Placebo, intervention Comorbid conditions: NR | | | Follow-up rate: 100 of 134 (74.6%) at quit date; NR for intervention period Important baseline differences: FTND lower for intervention group: 6.1 (2.4) vs 7.1 (2.4) [underlined: Outcomes of interest]; 1. Abstinence rate:; Post-quit day (randomization); Wk 6 (10): 19 of 66 (28.8%) placebo vs 23 of 68 (33.8%) intervention; Wk 30 (34): 11 of 66 (16.7%) placebo vs 8 of 68 (11.8%); When analysis was limited to the 100 subjects enrolled until quit date, there were no statistically significant differences in abstinence rates; 2. Medication adherence rate: NR; 3. Differential effects by gender: NR; 4. Differential effects by depression status:; No interaction effect for treatment by single vs recurrent depression or baseline depression status; 5. Differential effects by treatment sequencing: NA; Report adverse effects? Yes; - Dizziness, agitation, spaciness, diarrhea; - 7 placebo, 4 intervention dropped out by wk 4 due to AE | | | | | General comments: Table 2 gives AE rates but suspect scale Applicability cautions: No concerns Study-level quality assessment: Good Measure of smoking adequate? Yes Assessment of adverse effects adequate? No
Study ID: Duffy, Ronis, Valenstein, et al., 2006
Geographical location:; - University of Michigan, VAMC, Ann Arbor, MI; - VAMC, Dallas, TX; - VAMC, Gainesville, FL; Recruitment: Clinic waiting room at study sites Setting:; - Primary care; - Academic and nonacademic, mixed; Veterans clinics: Yes Study design: RCT Number of participants enrolled: 184 enrolled 91 usual care 93 intervention Duration of follow-up: 6 mo from end of intervention [underlined: Methods of assessment] Smoking status:; - Self-report; - Abstinent at least 1 mo to be “quitter,” reported at 6 mo follow-up; - No biochemical measure; Depression status: NR | Intervention description: Combined smoking, depression, alcohol abuse telephone counseling (n = 93) vs enhanced usual care of brief counseling and referral to appropriate services for substance use/abuse and/or depression (n = 91) All participants were nonterminal head and neck cancer patients Smoking cessation intervention: [underlined: Behavioral interventions] 45 min baseline assessment and brief counseling with RN using semistructured instruments CBT, 9–11 sessions, planned telephone counseling and workbook Therapist was RN trained specifically for intervention Topics included tobacco tactics, drinking decisions, and mood management using goal setting, self-monitoring, analyzing behavioral antecedents, coping, and social skills training [underlined: Drugs]; - Offered as needed; - Nicotine replacement and/or bupropion; Depression intervention: [underlined: Behavioral interventions]: None additional [underlined: Drugs] Offered antidepressants on individual basis (bupropion, paroxetine, fluoxetine, sertraline) [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] 45 min baseline assessment and brief counseling with RN using semistructured instruments Referred as needed to smoking cessation, alcohol treatment, or mental health evaluation according to insurance and ability to pay (options and time spent standardized) Handout listing all services available in area (e.g., Alcoholics Anonymous) [underlined: Drugs] Not specified as prescribed on individual basis Depression intervention: [underlined: Behavioral interventions] See above, dependent on individual referral [underlined: Drugs:] None specified Mean contact time/proportion of sessions completed: 77 of 93 (82.8%) completed all aspects of intervention Treatment sequencing: NA | | Inclusion criteria:; - Diagnosis head and neck cancer; - Comorbid smoking, depression, or problem drinking; - Older than age 18; - HDRS >20 or severe drinking; Exclusion criteria:; - Pregnant; - Non-English; - Terminal illness; - Unstable psychiatric illness; Age: 57 (9.9) Gender (n [%]) : Male 155 (84%) Race/ethnicity (n [%]): White 166, (90%) Other 18 (10%) Baseline depression assessment: Geriatric Depression Scale-short form; score > 4 at baseline and follow-up (69% of sample depressed) Smoking characteristics: Self report; 74% of sample Comorbid conditions (n [%]):; - Depression 127 (69%); - Alcohol 52 (28%) | | | Follow-up rate: 84% at 6 mo for total population Important baseline differences: None [underlined: Outcomes of interest]; - Quit rate at 6 mo for all smokers (n = 136); - Intervention, 35 of 74 (47%); - Usual care, 19 of 62 (31%); 1. Abstinence rate:; At 6 mo for those depressed at baseline (n = 64):; Intervention 51% (18 of 35); Usual care 17% (5 of 29); 2. Medication adherence rate:; NR; 3. Differential effects by gender: NR; 4. Differential effects by depression status: NR; 5. Differential effects by treatment sequencing:; Not done; Report adverse effects? No List | | | | | General comments: This study tried to treat smoking, alcohol abuse, and depression concomitantly in a group of head and neck cancer survivors Only 64 participants had depression and also smoked at baseline Depression was mild to moderate and excluded those with HDRS > 20 Used Geriatric Depression Scale-short form > 4 to define depressed Applicability cautions: Good; 52% vets, correct age, male; all head and neck cancer patients Study-level quality assessment: Good Measure of smoking adequate? No; no biochemical validation of self-report status; self-report alone may underestimate current smokers Assessment of adverse effects adequate? No
Study ID: Evins, Culhane, Alpert, et al., 2008
Geographical location: Boston, MA Recruitment:; - Advertisement; - Referral; Setting:; - Mixed; - Academic; Veterans clinics: No Study design: RCT Number of participants enrolled: 199 Duration of follow-up: 13 wk [underlined: Methods of assessment] Smoking status: 7 day self-report CO validated ≤ ppm Depression status: HAM-D-6: > 4 high ≤ 4 low | Intervention description: Intervention = 97 Comparator = 102 Blocked randomization on level of nicotine dependence, failed history of treatment with NRT and/or CBT, current or past UDD 13 sessions of group CBT + 8 wk NRT + 12 wk bupropion SR vs 13 sessions of group CBT + 8 wk NRT + placebo Smoking cessation intervention: [underlined: Behavioral interventions] 13 wk of group CBT with groups up to 6 patients plus weekly visit with study psychiatrist (session 1 treatment rationale; session 2, cognitive behavioral suggestions for using NRT; sessions 3 to 13, cognitive behavioral strategies of maintenance of abstinence) These CBT sessions did not address depression [underlined: Drugs]; - Bupropion 12 wk (150 mg/day for 3 days and then 150 mg BID); - NRT 8 wk (21 mg patches for wk 2 to 6; 14 mg patches wk 7 and 8; 7 mg patches wk 9 and 10); Depression intervention: None [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Same as above: 13 wk of group CBT with groups up to 6 patients plus weekly visit with study psychiatrist These CBT sessions did not address depression [underlined: Drugs]; - NRT 8 wk (21 mg patches for wk 2 to 6; 14 mg patches wk 7 and 8; 7 mg patches wk 9 and 10); - Placebo 12 wk (same schedule as bupropion); Depression intervention: None Mean contact time/proportion of sessions completed: NR, but 50% dropped out Treatment sequencing: NA | | Inclusion criteria:; - Ages 18 to 70; - Smoked > 10 cigarettes/day for more than 2 yr; - Lifetime diagnosis of UDD (so current and history of depression); - History of depression or current depression; Exclusion criteria:; - Substance use disorder; - Other psychiatric disorders; - Current use of nicotine-containing products, psychotropic medications, or behavioral smoking cessation treatment; Age: Mean (SD): 43 (11) Gender (n [%]): Female 97 (49%) Race/ethnicity (n [%]): NA Baseline depression assessment: HAM-D-6 Smoking characteristics:; - 7 day point prevalence; - FNTD; Comorbid conditions (n [%]): Lifetime anxiety 79 (40%) | | | Follow-up rate: 99 of 199 = 49.7% Important baseline differences: More men and fewer depression episodes in placebo arm [underlined: Outcomes of interest]; 1. Abstinence rate:; At 13 wk post-baseline: 36% bupropion and 31% placebo using intent to treat analyses; 2. Medication adherence rate:; NR; 3. Differential effects by gender: Not done; 4. Differential effects by depression status: Yes; - Current UDD:; 33% (15 of 45) bupropion vs 31% (14 of 45) in placebo were abstinent; - History of UDD:; 39% (20 of 52) bupropion vs 32% (18 of 57) in placebo were abstinent; 5. Differential effects by treatment sequencing: Not done; Report adverse effects? No | | | | | General comments: None Applicability cautions: Very high dropout rate Study-level quality assessment: Good Measure of smoking adequate? Yes Assessment of adverse effects adequate? NA
Study ID: Hall, Munoz, and Reus, 1994
Geographical location: San Francisco, CA Recruitment:; - Patients responding to “announcements”; - Referred by physician or friend; Setting:; - Research clinic; - Academic medical center; Veterans clinics: No Study design: RCT Number of participants enrolled: 149 Duration of follow-up: 8, 12, 26, 52 wk [underlined: Methods of assessment] Smoking status:; - Biologically verified self-report of 7-day abstinence from cigarettes: expired CO ≤ 10 ppm; - At 52 wk CO measured and urinary cotinine ≤ 60 ng/ml; Depression status:; - BDI-II NR at follow-up; - Profile of mood states reported | Intervention description: 5 sessions of small group smoking cessation treatment + 5 sessions of CBT mood management + nicotine gum vs 5 sessions of small group smoking cessation treatment + nicotine gum MDD history negative: Control n = 53 CBT n = 50 MDD history positive: Control n = 17 CBT n = 29 Smoking cessation intervention: [underlined: Behavioral interventions] Ten 2-hr sessions over 8 wk (2 x for first 2 wk) First 5 sessions were “standard” smoking treatment: information on smoking, gum use, quit plan Intervention was delivered by 1 MD from preventive medicine specialty and 1 PhD psychologist [underlined: Drugs]; - NRT, 2 mg gum as needed for 8 wk; - Taper at 9–12 wk; - Mo 4–6 carry “shelf” gum for high-risk situations; Depression intervention: [underlined: Behavioral interventions] 5 sessions of CBT focused on mood management:; - Monitoring of thoughts, daily activities, interpersonal contacts and mood; - Focus on increasing thoughts and activities related to healthy mood and to not smoking; - Increasing pleasant activities; - Increasing pleasant social contacts; - Relation training; - Identifying and modifying maladaptive thoughts; - Setting realist life goals (manual available); [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] 5 sessions, 8 wk Small group; only support; leader did not condone any specific suggestions or offered any [underlined: Drugs:] Gum as above Depression intervention: None Mean contact time/proportion of sessions completed: NR Treatment sequencing: NA | | Inclusion criteria:; - 10+ cigarettes per day; - Ages 18 to 65; Exclusion criteria:; - Heart disease; - Angina, vasospastic disease; - Current or past peptic ulcer; - Temporomandibular joint disease; - Hypertension; - Life-threatening illness; - Alcohol or drug problems in past 6 mo; - Current treatment for psychiatric problems; - History of psychiatric hospitalization in past yr; - Pregnant or nursing; - Current MDD screened out; Age: Mean (SD): 40.6 (9.2) Gender (n [%]): Men 71 (48%) Women 78 (52%) Race/ethnicity (n [%]): White 131 (88%) Baseline depression assessment:; - DIS used to assess history of MDD, n = 46 (31%) history positive; - BDI:; History positive n = 6.39 (5.9); History negative n = 4.58 (4.6); Smoking characteristics: 24.9 (10.9) cigarettes/day 26.7 (13.9) CO level FTND tolerance scale 6.4 (1.9) Regular smoking yr 22.1 (9.5) Comorbid conditions: NR | | | Follow-up rate: NR; subjects with missing data were coded as smoking Important baseline differences: NR [underlined: Outcomes of interest]; 1. Abstinence rate:; Wk 12 rates (from baseline); MDD history negative:; Control 26 of 53 (49%); CBT 23 of 50 (46%); MDD history positive:; Control 8 of 17 (47%); CBT 20 of 29 (69%); Wk 52; MDD history negative:; Control 13 of 53 (25%); CBT 8 of 50 (16%); MDD history positive:; Control 4 of 17 (24%); CBT 10 of 29 (34%); 2. Medication adherence rate:; NR; 3. Differential effects by gender: NR; 4. Differential effects by depression status:; See above for unadjusted rates; the diagnosis x treatment group interaction was significant; Among only those with MDD history positive, 10 of 29 (34%) vs 3 of 17 (18%) at 1 yr; 5. Differential effects by treatment sequencing: NA; Report adverse effects? No | | | | | General comments: None Applicability cautions:; - Current MDD or other psychiatric treatment excluded; - Volunteer reactive sample; Study-level quality assessment: Fair to poor Comments:; - Randomization and allocation NR; - Baseline characteristics by intervention NR; - Follow-up rates NR; - Adherence NR; - Dropout NR; Measure of smoking adequate? Yes Assessment of adverse effects adequate? NR
Study ID: Hall, Munoz, Reus, et al., 1996
Geographical location: San Francisco, CA Recruitment: Media, fliers, word of mouth Setting:; - Research clinic; - Academic medical center; Veterans clinics: No Study design: RCT Number of participants enrolled: 207, but 201 analyzed; 6 excluded because of protocol violations (e.g., use of nicotine patch) Duration of follow-up:; - 8 wk (treatment termination); - 12 wk post–treatment termination + 26 and 52 wk post–treatment termination; [underlined: Methods of assessment] Smoking status:; - Biologically verified self- report of 7-day abstinence from cigarettes: expired; CO ≤ 10 ppm; - At 52 wk CO measured and urinary cotinine ≤ 60 ng/ml; Depression status:; - BDI-II not related to MDD history; - Profile of mood states higher at wk 2 post-quit with increase for MDD history positive | Intervention description: 2 (behavioral treatments) x 2 (gum vs placebo) factorial design; stratified by MDD history and cigarettes smoked Both behavioral arms 10-session group over 8 wk; quit date set for third group session; groups 5–12 patients (Cell sizes in 2 x 2 NR; n’s below collapse across 1 treatment condition) MDD history negative: Health education (control) n = 74 CBT n = 83 Placebo gum n = 82 Active gum n = 75 MDD history positive: Control n = 23 CBT n = 21 Placebo gum n = 21 Active gum n = 23 Smoking cessation intervention: [underlined: Behavioral interventions] Ten 2-hr sessions based on Hall 1994 “Mood management” CBT focused as described in Hall 1994; “standard” smoking treatment: information on smoking, gum use, quit plan Intervention was delivered by weekly supervision from PhD psychologist including review of audiotapes [underlined: Drugs]; - NRT: 2 mg gum at session 3 (quit date) for 8 wk; - Chew at least 1 piece per hr for at least 12 hr/day during first 3 wk; - Use prn wk 4–8; - Taper at 9–12 weeks; - Mo 4–6 carry “shelf” gum for high-risk situations; - By 6 mo abstinent from all NRT; Depression intervention: [underlined: Behavioral interventions] 5 of CBT focused on mood management:; - Monitoring of thoughts, daily activities, interpersonal contacts and mood; - Focus on increasing thoughts and activities related to healthy mood and to not smoking; - Increasing pleasant activities; - Increasing pleasant social contacts; - Relation training; - Identifying and modifying maladaptive thoughts; - Setting realistic life goals (manual available); [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Group health education “Standard” smoking treatment: information on smoking, gum use, quit plan developed and modified each week Group leader provided health information and facilitated group discussion [underlined: Drugs] As above Depression intervention: None Mean contact time/proportion of sessions completed: NR Treatment sequencing: NA | | Inclusion criteria:; - 10+ cigarettes per day; - Ages 18 to 65; Exclusion criteria:; - Heart disease; - Ulcers; - Oral thrush; - Current alcohol or drug problems; - Hypertension; - Pregnancy; - Current mental health treatment; - Use of psychoactive drugs; - Physician letter indicating that patient is healthy; - Current MDD excluded; Age: Mean (SD): 39.7 (NR) Range: 22 to 65 Gender (n [%]): Women 105 (52%) Men 96 (48%) Race/ethnicity (n [%]): White 185 (92%) Baseline depression assessment:; - DIS used to assess history of MDD; 22% of 201 history positive; - BDI 6.71 (5.43); Smoking characteristics:; - 23.8 (9.8) cigarettes/day; - 27.2 (11.81) CO level; - Regular smoking yr 21 (NR); Comorbid conditions: NR | | | Follow-up rate: NR; subjects with missing data were coded as smoking Important baseline differences: NR [underlined: Outcomes of interest] No effect for treatment gum dose, MDD history, or interaction; 1. Abstinence rate:; Wk 12 rates (from baseline); MDD history negative:; Control: 26 of 74 (35%); CBT: 29 of 83 (35%); Placebo gum: 28 of 82 (34%); Active gum: 27 of 75 (36%); MDD history positive:; Control: 8 of 23 (35%); CBT: 10 of 21 (48%); Placebo gum: 11 of 21 (52%); Active gum: 7 of 23 (30%); Wk 52; MDD history negative:; Control: 17 of 74 (23%); CBT: 23 of 83 (28%); Placebo gum: 21 of 82 (26%); Active gum: 19 of 75 (25%); MDD history positive:; Control: 5 of 23 (22%); CBT: 7 of 21 (33%); Placebo gum: 7 of 21 (33%); Active gum: 5 of 23 (22%); 2. Medication adherence rate:; NR; 3. Differential effects by gender: NR; 4. Differential effects by depression status:; See above for unadjusted rates; the diagnosis x treatment group interaction was not significant; 5. Differential effects by treatment sequencing: NA; Report adverse effects? No | | | | | General comments: Caution: 2 x 2 factorial but data presented as if a 4-arm study, so each subject is double counted Applicability cautions:; - Current MDD or other psychiatric treatment excluded; - Volunteer reactive sample; - Participants had to pay $75 deposit; Study-level quality assessment: Fair Comments:; - Randomization and allocation NR; - Baseline characteristics by treatment group NR; - Follow-up rates NR; - Adherence NR; - Dropout NR; Measure of smoking adequate? Yes Assessment of adverse effects adequate? NR
Study ID: Hall, Reus, Munoz, et al., 1998
Geographical location: San Francisco, CA Recruitment:; - Public service announcements; - Newspaper ads; Setting:; - Research clinic; - Academic medical center; Veterans clinics: No Study design: RCT Number of participants enrolled: 199 Duration of follow-up:; - 8 wk (treatment termination); - 12 weeks post–treatment termination plus 26 and 52 wk post–treatment termination; [underlined: Methods of assessment] Smoking status:; - Biologically verified self-report of 7-day abstinence from cigarettes: expired CO ≤ 10 ppm; - Urinary cotinine ≤ 341 nmol/l; Depression status:; - BDI; - Profile of mood states reported for only 8 days after quit | Intervention description: 2 (CBT vs health education) x 2 (nortriptyline vs placebo) Drug/CBT (n = 51) MDD history positive n = 17 (33.3%) Drug/health education (n = 48) MDD history positive n = 15 (31.3%) Placebo/CBT (n = 52) MDD history positive n = 17 (32.7%) Placebo/health education (n = 48) MDD history positive n = 16 (33.3) Smoking cessation intervention: [underlined: Behavioral interventions] Group “mood management” CBT as described in Hall 1994 Ten 2-hr group sessions over 8 wk Group size 5–11 patients CBT focused on mood management skills to manage dysphoria and maintain nonsmoking and included methods to increase the frequency of pleasant activities and decrease relapse-related thoughts and techniques for increasing positive social contacts, decreasing negative contacts, and improving relationships. Intervention delivered by 3 PhD psychologists [underlined: Drugs] Double blind; MD visits wk 1, 2, 3 Nortriptyline hydrochloride at therapeutic dose for depression; 25 mg/day for 3 days; increased to 50 mg/day for 4 days Serum assessed at wk 2 Dose increased to 75 mg/day if therapeutic level not attained; increased to 100 mg/day if necessary at wk 6 Modal dose 100 mg/day; maintenance to wk 12 Taper during wk 13 (whenever active drug was titrated; someone in placebo was titrated) Depression intervention: [underlined: Behavioral interventions] 5 sessions of CBT (smoking/mood management) as above [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Group health education Group leader provided health information and facilitated group discussion Development of quit plan; modified quit plan each week but only five 90-min sessions (5–11 patients per group) over 8 wk. Methods included paper-and-pencil exercises, informational handouts, brief didactic presentations, homework assignments, and smoking monitoring [underlined: Drugs:] As above Depression intervention: [underlined: Behavioral interventions:] Drug as above Mean contact time/proportion of sessions completed: NR Treatment sequencing: NA | | Inclusion criteria:; - 10+ cigarettes per day; - Ages 21 to 65; Exclusion criteria:; - Heart disease or ECG abnormalities; - “Other reasons”; - Current mental health treatment; - Use of psychoactive drugs; - Current MDD; - Alcohol or other non-nicotine drug use; Age: Mean (SD): Drug + CBT 41.7 (9.4) Drug + health education: 40.7 (9.6) Placebo + CBT: 40.0 (9.9) Placebo + health education: 39.4 (9.7) Gender (n [%]): Women n = 110 (55%) Men n = 89 (45%) Race/ethnicity (n [%]): White 173 (89%) Baseline depression assessment: DIS used to assess history of MDD: MDD history positive n = 65 (32.7) BDI: MDD history positive n = 7.2 (5.6) MDD history negative n = 5.5 (2.2) Smoking characteristics: Range of mean (SD) for the 4 groups:; - FTND 5.4 (2.2) to 5.2 (2.2); - Yr smoking 21.7 (10.0) to 23.0 (10.7); - Daily cigarettes 21.1 (7.6) to 24.9 (12.1); Comorbid conditions: NR | | | Follow-up rate: N = 47 (24%) dropped out of treatment No difference in psychological intervention or history of MDD in dropout rates but dropout higher in placebo drug (30%) vs active drug (17%) (or = 2.01; 1.05–4.06) Important baseline differences: None [underlined: Outcomes of interest]; 1. Abstinence rate:; ITT analyses abstracted here:; Wk 12 rates (from baseline); MDD history negative:; Drug + CBT 56%, 19 of 34; Drug + health education 61%, 20 of 33; Placebo + CBT 20%,7 of 35; Placebo + health education 31%, 10 of 32; MDD history positive:; Drug + CBT 47%, 8 of 17; Drug + health education 47%, 7 of 15; Placebo + CBT 41%,7 of 17; Placebo + health education 19%,3 of 16; Wk 64; MDD history negative:; Drug + CBT 35%, 12 of 34; Drug + health education 36%, 12 of 33; Placebo + CBT 20%, 7 of 35; Placebo + health education 22%, 7 of 32; MDD history positive:; Drug + CBT 24%, 4 of 17; Drug + health education 20%, 3 to 15; Placebo + CBT 29%, 5 of 17; Placebo + health education 13%, 2 of 16; 2. Medication adherence rate:; Capsules did not differ by condition or drug (active vs placebo); 3. Differential effects by gender:; Gender by MDD history interaction significant; MDD history positive women had poorer abstinence rates than MDD history negative (or =2.05; 1.32–3.23) but not for MDD history positive men (p = 0.20); Women:; Wk 12; MDD history positive 38%; MDD history negative 53%; Wk 64; MDD history positive 20%; MDD history negative 37%; Men:; Wk 12; MDD history positive 61%; MDD history negative 52%; Wk 64; MDD history positive 37%; MDD history negative 31%; 4. Differential effects by depression status:; See above for unadjusted rates for main effect for drug; 24% vs 12% placebo achieved continuous abstinence; The diagnosis (i.e., MDD history) by psychological treatment by drug interaction was not significant; Behavioral treatment condition by MDD history was significant; MDD history positive assigned to CBT did as well as MDD history negative; MDD history positive assigned to control were less likely to be abstinent than those assigned to CBT; Drug by diagnosis was not significant; The diagnosis x treatment group interaction was not significant; 5. Differential effects by treatment sequencing: NA; Report adverse effects?; - Measured by checklist; - Dry mouth 78% drug vs 33% or 7.0; 95% CI 3.73 to 13.17; - Lightheaded 49% vs 22% or 2.42 1.85–6.35; - Shaky hands 23% vs 11% or 2.42; 1.11–5.29; - Blurry vision 16% vs 6% 3.00; 1.12–7.99 | | | | | General comments: Randomization stratified by depression status Applicability cautions:; - Current MDD or other psychiatric treatment excluded; - Volunteer reactive sample; Study-level quality assessment: Good Comments: Adherence rate to behavioral treatment NR Measure of smoking adequate? Yes Assessment of adverse effects adequate? Yes
Study ID: Hall, Tsoh, Prochaska, et al., 2006
Geographical location: San Francisco, CA Recruitment:; - Provider referral; - Invitation letters to clinic patients; - Flyers in clinics; - Paid $150; Setting:; - Mental health outpatient clinics; - Academic and nonacademic; Veterans clinics: No Study design: RCT Number of participants enrolled: 322 Duration of follow-up: 18 mo [underlined: Methods of assessment] Smoking status:; - Biologically verified self-report of 7-day abstinence from cigarettes: expired CO ≤ 10 ppm; - Interviewers blind to treatment group; Depression status: BDI-II | Intervention description: Brief contact and referral control (n = 159) vs staged-care intervention (n = 163) Smoking cessation intervention: [underlined: Behavioral interventions] Computerized motivational feedback based on the stages of change model (15 min session given at baseline, 3, 6, and 12 mo Patients at contemplation stage were also offered counseling Cessation treatment program of CBT; six 30 min sessions of individual treatments over 8 wk offered by one of two therapists (MA-level psychologist or PhD psychologist) CBT consisted of quit plan that was iteratively revised, quite date, self-tests about reasons for smoking, information about risks/benefits of quitting, information on nutrition and exercise, mood monitoring, discussion of ways to increase pleasant moods and decrease negative ones, use of behavioral skills to reduce relapse risk, and relation and social support skills. [underlined: Drugs]; - NRT; - If smoked 10+ cigarettes got 21 mg patch for 6 wk, 14 mg wk 7–8; 7 mg wk 9–10; - If failed NRT, could request bupropion (dose NR); Depression intervention: None [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Brief contact; list of referrals to smoking cessation programs and stop smoking guide [underlined: Drugs]: None Depression intervention: None Mean contact time/proportion of sessions completed: NR Treatment sequencing: See above | | Inclusion criteria:; - Diagnosis of current depression based on PRIME MD; - Smoked 1+ cigarettes/day in week prior to enrollment; - Enrollment as a patient in one of four participating sites; Exclusion criteria:; - Under age 18; - Non-English speaking; - History of bipolar; - Contraindicated to use of pharmacological treatments; - Dementia or other disorders interfering with comprehension of materials; Age: Mean (SD): Control (n = 159) 42.2 (12.8) Staged care (n = 163) 41.5 (12.4) Median: NR Range: NR Gender (n [%]): Male 98 (30.4%) Female 224 (69.6%) Race/ethnicity (n [%]): White 220 (68.3%) Baseline depression assessment: PRIME-MD + to be enrolled BDI-II: Control 21.4 (10.9) Staged care 20.6 (11.7) DIS DSM-IV + MDD: Control 155 (97.5) Staged care 152 (93.3) Current MDD: Control 133 (83.7) Staged care 135 (82.8) Recurrent MDD: Control 89 (57.4) Staged care 79 (52.0) Smoking characteristics: FTND: Control 4.2 (2.6) Staged care 3.8 (2.4) Number of cigarettes/day: Control 15.3 (10.3) Staged care 15.8 (10.0) CO at baseline: Control 15.2 (10.2) Staged care 15.5 (9.9) Comorbid conditions: NR | | | Follow-up rate: 3 mo: Control (n = 129; 81%) Intervention (n = 138; 85%) 6 mo: Control (n = 120; 75%) Intervention (n = 125; 77%) 12 mo: Control (n = 112; 70%) Intervention (n = 113; 69%) 18 mo: Control (n = 110; 69%) Intervention (n = 122; 75%) Important baseline differences: Control had higher % of lifetime nicotine dependence: 74.7% vs 64.2% (not correlated with outcomes) [underlined: Outcomes of interest]; 1. Abstinence rate; Rates based on ITT analyses (missing = smoker); Intervention:; 3 mo: 22 of 163 (13.5%); 6 mo: 23 of 163 (14.11%); 12 mo: 23 of 163 (14.11%); 18 mo: 30 of 163 (18.4%); Control:; 3 mo: 15 of 159 (9.43%); 6 mo: 25 of 159 (15.73%); 12 mo: 15 of 159 (9.43%); 18 mo: 21 of 159 (13.21%); Gee model:; Main effect for treatment at 12 and 18 mo (completed only on responders); OR = 4.459 (95%); CI = 1.04 to 19.93; P = 0.0441; 2. Medication adherence rate:; NR; 3. Differential effects by gender: NR; 4. Differential effects by depression status:; - BDI-II not related to outcomes; - Analyses conducted in only MDD (n = 307) with same pattern of results; results not shown; 5. Differential effects by treatment sequencing: NA; Report adverse effects? No | | | | | General comments: None Applicability cautions:; - Patients recruited from large HMO; - Patients did not need to have intention to quit to enroll; Study-level quality assessment: Good Measure of smoking adequate? Yes Assessment of adverse effects adequate? NR
Study ID: Hayford, Patten, Rummans, et al., 1999
Geographical location: Three U.S. sites: Palo Alto, CA Rochester, MN Morgantown, WV Recruitment: Advertisement Setting:; - Mental health, primary care, mixed; - Academic and nonacademic; Veterans clinics: No Study design: RCT, 4 arms Number of participants enrolled: 742 volunteers 615 eligible and randomized Duration of follow-up: 3 mo and 12 mo from baseline [underlined: Methods of assessment] Smoking status: Self-reported abstinence for 7 days verified by CO level ≤ 10 ppm Depression status: BDI-21 item | Intervention description: 100 mg bupropion + behavioral intervention (n = 153) vs 150 mg + behavioral intervention (n = 153) vs 300 mg + behavioral intervention n = 156) vs placebo (n = 153) Smoking cessation intervention: [underlined: Behavioral interventions]; - Set target quit date after 1 wk of medication; - Personalized message to stop smoking; - Self-help materials based on NCI program; - Brief in-person individual counseling (10–15 min) by study assistant at weekly visits x 7 wk, then at 8, 12, 26, and 52 wk; - Telephoned 3 days after target quit date and at 4, 5, 7, 8, 9, 10, and 11 mo; [underlined: Drugs]; - Bupropion SR 50 mg BID; - Bupropion SR 150 mg am + placebo pm; - Bupropion SR 150 mg daily x 3 days, then 150 mg BID; - All drugs given for 7 wk; Depression intervention: None [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Same as intervention groups [underlined: Drugs] Placebo BID for 7 wk, n = 153 Depression intervention: None Mean contact time/proportion of sessions completed: 467 of 615 (75%) completed 7 wk intervention Treatment sequencing: NA | | Inclusion criteria:; - Age ≥ 18; - Smoked ≥ 15 cigarettes/day for past yr; - Motivated to stop smoking; - Good general health; Exclusion criteria:; - History of head trauma, predisposition to seizures, anorexia nervosa, or bulimia; - Current depression; - Pregnancy; - History of alcohol or substance abuse within past yr; - Personal or family history of seizure disorder; - Psychotropic medication use or NRT; - Previous use of bupropion; - Use of other tobacco products; Age: Mean (SD): 42 to 43 Median: NR Range: NR Gender (n [%]): Female 336 (54.6%) Race/ethnicity (n [%]): White 591(96%) Baseline depression assessment: BDI-21, score range 0–63 Mean (SD) ranges from 4.1 (4.2) to 4.7 (5.0) SCID for lifetime MDD, total n = 114 Smoking characteristics: Mean (SD) cigarettes/day range from 26.2 (8.5) to 27.5 (9.6) Previous serious quit attempts range from 3.5 (3.4) to 4.3 (5.4) FTND range from 7.1 (1.7) to 7.3 (1.7) Comorbid conditions (n [%]): Lifetime alcohol dependence, n = 60 | | | Follow-up rate: 396 of 615 (64%) completed 12 mo follow-up Completion varied by bupropion group: 57% (100 mg), 65% (150 mg), 64% (300 mg), 71% (placebo), p = 0.01 Important baseline differences: None between randomized groups; there were important differences between those with and without history of MDD or alcohol dependence (age, gender); however, mean changes in BDI scores did not significantly differ from zero for any group [underlined: Outcomes of interest]; 1. Abstinence rate:; 3 and 12 mo rates (% of randomized); Placebo: 14.4%;12.4%; 100 mg: 24.2%; 19.6%; 150 mg: 26.1%; 22.9%; 300 mg: 29.5%; 23.1%; p = 0.01 at 3 mo; p = 0.06 at 12 mo for all 4 groups; 150 mg and 300 mg doses statistically significant compared to placebo at all time points; 12 mo rates for participants with history of MDD; Placebo: 2 of 28 (7%); 100 mg: 4 of 28 (14%); 150 mg: 5 of 19 (26%); 300 mg: 4 of 20 (20%); 12 mo rates for participants with history of MDD and alcohol dependence; Placebo: 1 of 3 (33%); 100 mg: 2 of 7 (28.6%); 150 mg: 4 of 7 (57%); 300 mg: 2 of 10 (20%); 2. Medication adherence rate:; NR; 3. Differential effects by gender: NR; 4. Differential effects by depression status: NR; 5. Differential effects by treatment sequencing: NA; Report adverse effects? Yes Discontinued due to AE: Placebo: 8 (5%) 100 mg: 9 (6%) 150 mg: 7 (5%) 300 mg: 13 (8%) Headache, insomnia*, rhinitis, dry mouth*, and anxiety were most common (* = statistically significantly more) Other: Among those continuously abstinent (n = 103), there was a dose x time interaction (p = 0.04) showing less weight gain as bupropion dose increased | | | | | General comments: Effect of dose was dependent on diagnosis group Applicability cautions:; - Mean age < 45; - 96% white; - 55% female; Study-level quality assessment: Good Comments:; - Allocation concealment not specified; - Differential follow- up rate, if dropout, assumed to be smoking and would bias against intervention; - Funded by Glaxo Wellcome and included industry investigator(s); Measure of smoking adequate? Yes Assessment of adverse effects adequate? Fair; measured depressive symptoms and weight change but little detail on other AE measures
Study ID: Kinnunen, Doherty, Militello, et al., 1996
Geographical location: Boston, MA Recruitment: Advertisement Setting: NR Veterans clinics: No Study design: Secondary analysis of RCT Number of participants enrolled: 269 (93 depressed; 176 nondepressed) Duration of follow-up: 3 mo post–quit date [underlined: Methods of assessment] Smoking status:; - History and expired CO; - Relapse defined as “reestablished a regular pattern of smoking”; defined as ≥ 7 consecutive days; Depression status: CES-D score | Intervention description: Counseling + nicotine gum 2 mg vs counseling + nicotine gum 4 mg; combined gum (n = 178) vs counseling + placebo (n = 91) Smoking cessation intervention: [underlined: Behavioral interventions] One-time brief individual behavioral counseling: behavioral-cognitive procedures for coping with urges, cravings and withdrawal symptoms; help with individual concerns about quitting, such as weight gain; no further information given [underlined: Drugs]; - Nicotine gum 2 mg ad lib; target usage of 9–15 pieces/day; - Nicotine gum 4 mg ad lib; target usage of 9–15 pieces/day; Depression intervention: None [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Same as intervention group [underlined: Drugs] Matching placebo gum ad lib; target usage of 9–15 pieces/day Depression intervention: None Mean contact time/proportion of sessions completed: NR Treatment sequencing: NA | | Inclusion criteria:; - Smoked ≥ 5 cigarettes/day; - Good health; - Age ≥ 20; Exclusion criteria: NR Age: Mean (SD) | | | Follow-up rate: NR Important baseline differences: NR for intervention groups Depressed patients were more likely to be female, older, and unmarried than the nondepressed [underlined: Outcomes of interest]; 1. Abstinence rate:; Depressed subgroup (n = 93) at 90 days post–quit date:; - Placebo: 4 of 33 (12.5%); - Nicotine gum 2 mg and 4 mg groups: 17 of 59 (29.5%); 2. Medication adherence rate:; Recommended gum use: 9 to 15 pieces/day; Average daily gum used for all groups at days 7, 30, 60, 90 was 8.1 pieces, 7.8 pieces, 6.2 pieces, 4.7 pieces, respectively; 3. Differential effects by gender: NR; 4. Differential effects by depression status: NR; 5. Differential effects by treatment sequencing: NA; Report adverse effects?; - 7 day change in CES-D scores; - Placebo group (depressed): no significant change, Tukey p = 0.99; - Nicotine group (depressed): lower scores, Tukey p = 0.00003 | | | | | General comments: None Applicability cautions:; - Mean age 40; - > 50% female; - > 80% white; Study-level quality assessment: Good Measure of smoking adequate? Atypical definition; less stringent than other studies Assessment of adverse effects adequate? No; only assessed 7 day change in CES-D scores
| | | Overall | Depressed
| | | 40.4 (12.6) | 41.6 (12.7)
| | | Gender (n [%]):
| | | Female
| | | Overall | Depressed
| | | 145 (51%) | 56 (61%)
| | | Race/ethnicity (n [%]):
| | | White
| | | Overall | Depressed
| | | 221 (82%) | 74 (80%)
| | | Black
| | | Overall | Depressed
| | | 29 (11%) | 11 (12%)
| | | Other
| | | Overall | Depressed
| | | 19 (7%) | 8 (8%)
| | | Baseline depression assessment: CES-D, 20 items, 0–60 Smoking characteristics: Mean cigarettes: 22 (10.4) Mean duration: 23.1 yr (4.0) FTND (depressed group): 5.6 (2.4) Comorbid conditions: NR
Study ID: Kinnunen, Korhonen, and Garvey, 2008
Geographical location: Boston, MA Recruitment: Advertisement Setting:; - Clinic type NR; - Academic (university hospital); Veterans clinics: No Study design: RCT Number of participants enrolled: Total n = 608 Depressed = 196 Nondepressed = 412 Duration of follow-up: 3, 6, 9, and 12 mo post–quit date [underlined: Methods of assessment] Smoking status: Self report 7-day point prevalence validated by CO monitor Depression status: CES-D score | Intervention description:; - Nicotine gum, 2–4 mg (collapsed) (n = 405); - Placebo gum (n = 203); Smoking cessation intervention: [underlined: Behavioral interventions] Individual brief (5–10 min) counseling at each in-person visit (1, 7, 14, 30, 60, 90, 180, 270, and 365 days post–quit date) Booklet “Clearing the Air” on how to stop smoking was provided [underlined: Drugs] NRT gum, 2 or 4 mg; groups collapsed across arms as parent study showed no difference in outcome between groups Depression intervention: None [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Individual brief (5–10 mi) counseling at each in-person visit Booklet “Clearing the Air” on how to stop smoking was provided [underlined: Drugs] Placebo gum Depression intervention: None Mean contact time/proportion of sessions completed: NR Treatment sequencing: NA | | Inclusion criteria:; - Age ≥ 20; - Good health; - Smoke ≥ 5 cigarettes/day; Exclusion criteria:; - Serious medical condition; - Use of psychiatric medications; Age: Mean (SD); - NR for whole population; - Depressed 38.5(11.3); - Nondepressed 41.9 (12.0); Gender (n [%]): Female 312 (51%) Depressed female 110 (56.1%) Nondepressed female 202 (49%) Race/ethnicity (n [%]): | | | Follow-up rate: NR; 3 withdrew for adverse effects Important baseline differences: Depressed group was younger, single, and had less education; P < 0.05 [underlined: Outcomes of interest]; 1. Abstinence rate:; - At 3 mo:; In figure, but numbers not given; would have to extrapolate numbers; - At 12 mo:; Nondepressed with NRT = 58 of 279 (20.1%); Nondepressed placebo = 20 of 133 (15.1%); Depressed with NRT = 12 of 126 (9.8%); Depressed with placebo = 4/70 (5.7%); 2. Medication adherence rate:; NR; 3. Differential effects by gender:; NR, but effect of depression no longer significant when adjusted for differences in marital status and education; 4. Differential effects by depression status: NR; 5. Differential effects by treatment sequencing: NR; Report adverse effects? Yes 3 questionable reactions to NRT gum | | | | | General comments: Supplemented information using Garvey 2000 Applicability cautions:; - Majority female; - 80% White; Study-level quality assessment: Good Measure of smoking adequate? Yes Assessment of adverse effects adequate? Yes
| | | | [underlined: Depressed] | [underlined: Nondepressed]
| | | White | 154 (78.6%) | 338 (82%)
| | | Black | 28 (14.3%) | 51(12.4%)
| | | Other | 14(7.1%) | 23 (5.6%)
| | | Baseline depression assessment: CES-D, range 0–60; ≥ 16 classified as depressed; 32% depressed at baseline No information on history of depression or substance abuse Smoking characteristics:; - Expired CO > 8 ppm; - Number of cigarettes/day; - FTND; Comorbid conditions (n [%]): Depression 195 (32%)
Study ID: MacPherson, Tull, Matusiewicz, et al., 2010
Geographical location: NR; multicenter? Recruitment: Advertisement Setting:; - Mental health, primary care, mixed; - Academic and nonacademic; Veterans clinics: No Study design: RCT Number of participants enrolled:; - 68 randomized; - 26 dropped out prior to treatment: 17 from standard treatment (ST); 9 from behavioral activation treatment for smoking (BATS); Duration of follow-up:; - 26 wk; - Measurements at baseline (wk 1), quit date (wk 4), 4 mo post–quit date (wk 16, but wk 12 post 8-wk treatment), and 6.5 mo post–quit date (wk 26, but wk 22 post 8-wk treatment); [underlined: Methods of assessment] Smoking status:; - 7 day self-reported point prevalence abstinence rates at 16 and 26 wk post–quit date; - Verified via expired CO; - Saliva samples for cotinine analysis at wk 16 and 26; - Verification of abstinence defined as CO ≤10 ppm and cotinine ≤15 ng/ml; Depression status: BDI-II | Intervention description: 2 arms:; - ST: nicotine patch + 8 wk CBT (n = 33); - BATS: nicotine patch + 8 wk CBT + behavioral activation (BA) (n = 35); Matched for overall contact time; same specially trained therapists led both types of sessions; taped to ensure protocol followed (20% viewed) Smoking cessation intervention: [underlined: Behavioral interventions] 30 min CBT (described in ST below, excluding relaxation; re-placed with BA) 30 min of BA (adapted from Lejuez et al. 2001) Group therapy Contact time 8 wk Intervention delivered by psychology doctorate-level therapist Techniques specific to BA included activity monitoring (behavioral checkout form used for goal setting, planning, and monitoring throughout); identifying enjoyable activities and quit-related, abstinence-maintaining, and relapse-prevention activities [underlined: Drugs] Transdermal nicotine patch for 8 wk from quit date (wk 4) with an initial dose of 21 mg for 4 wk, followed by 14 mg for 2 wk, and 7 mg for 2 wk Participants who smoked on average 10–12 cigarettes/day started with the 14-mg patch for the first 6 wk per manufacturer’s recommendations Depression intervention: Nothing additional to BA [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] 60 min CBT Group therapy Contact time 8 sessions Intervention delivered by psychology doctorate-level therapist Techniques included self-monitoring, identifying effective and in-effective cessation strategies from prior quit attempts, relaxation, coping with triggers, identifying social support for cessation, making lifestyle changes (such as increasing physical activity and reducing stress), relapse prevention, and homework [underlined: Drugs:] Same as intervention Depression intervention: [underlined: Behavioral interventions]: None Mean contact time/proportion of sessions completed: ST: 11 of 16 completed 7 to 8 sessions BATS: 17 of 26 completed 7 to 8 sessions Treatment sequencing: NA Other notes about interventions: BA measured by Environmental Reward Observation Scale | | Inclusion criteria:; - Ages 18 to 65; - Smoke ≥ 10 cigarettes/day; - Smoke ≥ 1 yr; - BDI-II ≥ 10; - No current SCID-NP diagnosis; Exclusion criteria:; - BDI ≤ 7; - SCID Axis I diagnosis; - Current use of psychotropic medications; - Current psychotherapy; - Contraindication to nicotine patch; - Use of smoking pharmacotherapy; - Use of other types of tobacco; Note: Demographics were not reported by entire population Age: Mean (SD) | | | Follow-up rate: For abstinence obtained by bio-chemical verification of smoking status (others considered still smoking): | | | | | General comments: None Applicability cautions: Age, gender, race, education and income all similar to veteran population Study-level quality assessment: Good Comments:; - Repeated measures analyses using GEEs; - Random allocation; - Blinding not possible; - Completers did not differ from ITT by demographics; Measure of smoking adequate? Yes; only those whose smoking status was biochemically verified were considered abstinent at each time point, whereas the 26 missing participants who dropped out prior to treatment were considered as having smoked in ITT analyses Assessment of adverse effects adequate? NR
| | | ST | BATS | | Wk 1 | | 78.6%
| | | 42.6 (11.5) | 45.0 (12.2) | | Wk 4 | | 83.3%
| | | Gender (n [%]): | | | Wk 16 | | 61.9%
| | | Female: | | | Wk 26 | | 64.3%
| | | ST | BATS | | Important baseline differences: None (see Table 1) [underlined: Outcomes of interest] 1) Abstinence rate:
| | | 16 (48.5%) | 17 (48.6%) | | | | ST | BATS | OR
| | | Race/ethnicity (n [%]): | | | ITT:
| | | African American: | | | Wk 16 | | 3/33 | 4/35 | 2.71
| | | ST | BATS | | Wk 26 | | 0/33 | 5/35 | ---
| | | 25 (75.8%) | 24 (69.7%) | | Completers:
| | | Baseline depression assessment: | | | Wk 16 | | 6.3 | 15.4 | 2.71
| | | BDI, 0–62, score < or > 10: | | | Wk 26 | | 0.0 | 19.2 | ---
| | | ST | BATS | | Rates decreased over time, but interaction between treatment and time was ns BATS >ST (wk 1-wk 26 post–quit date)
| | | 10.4 (7.5) | 10.8 (5.2) | | abs OR | | 95% CI | | p
| | | Smoking characteristics: | | | 3.59 | | (1.22, 3.73) | | 0.02
| | | FTND: | | | Continuous abstinence rates did not differ between treatments (p = 0.11) Depression: An interaction between treatment condition and the linear effect of time revealed that the reduction in depressive symptoms over time was greater for BATS than for ST participants (see Table 4, Figure 2) This analysis is in completers (n = 42)
| | | ST | BATS | | BDI beta | | SE | t | p
| | | 6.1 (2.1) | 5.8 (1.8) | | −1.99 | | 0.86 | −2.31 | 0.02
| | | Cigarettes/day: | | | 2) Medication adherence rate: See mean contact time 3) Differential effects by gender: NR by treatment 4) Differential effects by depression status: NR by treatment 5) Differential effects by treatment sequencing: NA Report adverse effects? No List
| | | ST | BATS
| | | 17.3 (8.1) | 18.8 (7.1)
| | | Comorbid conditions: All were excluded
Study ID: Munoz, Marin, Posner, et al., 1997
Geographical location: San Francisco, CA Recruitment:; - TV; - Radio; - Newspaper; - Bulletin boards; - Health fairs; Setting: Community Veterans clinics: No Study design: RCT Number of participants enrolled: 136 Duration of follow-up: 3 mo, 6 mo [underlined: Methods of assessment] Smoking status: Self-report of 7 day abstinence from cigarettes using mailed self-monitoring charts; saliva cotinine using 14 ng/ml as cut point but results not reported using this method Depression status: CES-D | Intervention description: Mailed smoking cessation guide and mood management guide (immediate) vs smoking cessation guide and mood management guide at 3 mo (delayed) Immediate vs delayed: N = 71 (54 MDE) vs n = 65 (52 MDE) Incentives:; - $2 for each 2 wk chart up to 6 charts in mood management; - $10 for each assessment a 3 mo and 6 mo; - $10 for saliva sample; Smoking cessation intervention: [underlined: Behavioral interventions] The “GUIA” (Guia Para Dejar de Fumar), a 36-page booklet from NCI (2002), is an anti-smoking brochure published in Spanish that includes reasons to quit, preparing to quit, techniques to resist the urge to smoke as a result of social situations, and changes in diet and exercise to avoid weight gain Mood management intervention, “Tomando Control de Su Vida,” an audio cassette on how to use materials, 30-minute relaxation exercise, self-monitoring of cigarette use booklet, pleasant activity guide, and monitoring tool A call was placed to verify receipt of materials and answer questions [underlined: Drugs:] None Depression intervention: None (note that we have classified the mood management module as part of the smoking cessation intervention, but it could be classified as a depression intervention) [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] GUIA plus delayed (3 mo) mood management; essentially a waitlist control [underlined: Drugs:] None Depression intervention: None Mean contact time/proportion of sessions completed: NR Treatment sequencing: NA | | Inclusion criteria:; - Age 18+; - 3+ cigarettes/day; - Completely or very sure they wanted to stop smoking within 3 mo; - Able to read Spanish; - Have access to audiotape player; - Live in Bay area; Exclusion criteria: None Age: Mean (SD): 35.3, SD = NR Gender (n [%]): Women 52 (38.2%) Men 84 (61.8%) Race/ethnicity (n [%]): Latino 136 (100%) Baseline depression assessment: Modified DIS CES-D for level of depressive symptoms Immediate: 21.5 (14.9) Delayed: 20.7 (12.5) Lifetime MDE n = 106 Current = 53 History = 53 No MDE history = 30 Smoking characteristics: Number of cigarettes/day 14.1 (8.2) Comorbid conditions: NR | | | Follow-up rate: Not clearly reported Important baseline differences: Delayed group had lower education and was less likely to be employed [underlined: Outcomes of interest] 1) Abstinence rate: (by self report) | | | | | General comments: Stratified randomization (no history of MDE vs history of or current MDE) Applicability cautions; Spanish speaking only Study-level quality assessment: Fair Comments:; - Randomization and allocation concealment procedures not well described; - No assessment of cotreatments (e.g., NRT); - Follow-up rates not clearly reported; - Biochemical verification done, but results not reported; Measure of smoking adequate? Yes; but not clearly reported Assessment of adverse effects adequate? NA
| | | | | | Immediate (3 mo)
| | | | | | No MDE | | | 4 of 17
| | | | | | Current | | | 4 of 28
| | | | | | MDE history | | | 8 of 26
| | | | | | Immediate (6 mo)
| | | | | | No MDE | | | 3 of 17
| | | | | | Current | | | 5 of 28
| | | | | | MDE history | | | 10 of 26
| | | | | | Delayed (3 mo)
| | | | | | No MDE | | | 1 of 13
| | | | | | Current | | | 3 of 25
| | | | | | MDE history | | | 3 of 27
| | | | | | Delayed (6 mo)
| | | | | | No MDE | | | 2 of 13
| | | | | | Current | | | 2 of 25
| | | | | | MDE history | | | 2 of 27
| | | | | | 2) Medication adherence rate: Not clearly reported Those returning filled out materials in immediate group vs those that did not = 45% vs 14% abstinence at 3 mo 3) Differential effects by gender: NR 4) Differential effects by depression status: See above for unadjusted results 5) Differential effects by treatment sequencing: NA Report adverse effects? NR
Study ID: Saules, Schuh, Arfken, et al., 2004
Geographical location: NR; multisite? Recruitment: Advertisement Setting:; - Mental health clinic; - Academic; Veterans clinics: No Study design: RCT Number of participants enrolled: 150 Duration of follow-up: 3, 6, and 12 mo post–quit date [underlined: Methods of assessment] Smoking status: Nonsmoking defined as self-reported abstinence combined with CO < 10 ppm Depression status: BDI | Intervention description: 3-arm study investigated the addition of fluoxetine to standard treatment to improve smoking cessation in smokers with depression: Fluoxetine (20 mg) + NRT + CBT (n = 48) Fluoxetine (40 mg) + NRT + CBT (n = 51) Placebo + NRT + CBT (n = 51) Smoking cessation intervention: [underlined: Behavioral interventions] 6 wk of group CBT started 2 wk prior to quit date delivered by trained therapists with treatment manual; no further information given [underlined: Drugs]; - 14 wk of either 20 mg or 40 mg of fluoxetine started 4 wk before quit date; - 10 wk of standard (15 mg dose) transdermal NRT started at quit date; 6 wk on 15 mg, then 2 wk 10 mg, and 2 wk 5 mg; Depression intervention: [underlined: Behavioral interventions] Nothing in addition to standard CBT (fluoxetineis antidepressant, however) [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Same as intervention group [underlined: Drugs]; - 14 wk of placebo started 4 wk before quit date; - Standard transdermal patch NRT as above; Depression intervention: [underlined: Behavioral interventions] Same as intervention; nothing in addition to standard CBT Mean contact time/proportion of sessions completed: 60% completed active phase; no difference between groups Treatment sequencing: NA | | Inclusion criteria:; - Ages 21 to 65; - ≥ 15 cigarettes/day; - Expired CO ≥ 15 ppm; Exclusion criteria:; - Psychiatric episode in last 6 mo; - Current psychiatric medication use; - Pregnancy; - Poor comprehension; - Any clinically significant medical condition; Age: Total pop (mean) 39.78 SDs NR Range: 21 to 65 | | | Follow-up rate: Follow-up rates NR for 3, 6, 12 mo follow-ups Important baseline differences: Higher BDI in placebo group; F(2,129) = 3.39, p = 0.037 [underlined: Outcomes of interest] At 15 wk from start of study, smoking cessation = 40%; 1. Abstinence rate:; At 15 wk:; Total (n = 150); Placebo = 35.4%; 20 mg fluoxetine = 43.1%; 40 mg fluoxetine = 43.1%; History of MDD (n = 30); Placebo = 37.5%; 20 mg fluoxetine = 54.5%; 40 mg fluoxetine = 54.5%; But these n’s are small ~ 10; 2. Medication adherence: NR; 3. Differential effects by gender: None; 4. Differential effects by depression status: None; 5. Differential effects by treatment sequencing: NA; Report adverse effects? Yes; but only that they were lower in both fluoxetine groups compared to placebo (p = 0.038) using the Minnesota Tobacco Withdrawal Symptom Checklist | | | | | General comments: Population not depressed (BDI score = 4.92 and only 20% had a history of depression), but results given by whether or not history of MDD was present Subjects were paid $150 to complete, $25 for follow-up, and $50 at final visit Applicability cautions: College educated, mean = 79.3% Study-level quality assessment: Fair Comments:; - No rates of treatment discontinuation by arm; - Selective outcome reporting: Did not report smoking rates by arm across 3, 6, 12 mo follow-ups.; - Did not report loss to follow-up; Measure of smoking adequate? Yes; cotinine Assessment of adverse effects adequate? Assessment method not given; reported that number of AEs did not differ between groups
| | | Placebo | 20mg | 40mg
| | | 40.85 | 40.44 | 38.44
| | | Gender (n [%]):
| | | Female:
| | | Placebo | 20mg | 40mg
| | | 23 (44.7%) | 31(60.8%) | 27(56.9%)
| | | Race/ethnicity (n [%]):
| | | White:
| | | Placebo | 20mg | 40mg
| | | 78.3% | 74.5% | 67.3%
| | | Black:
| | | Placebo | 20mg | 40mg
| | | 21.7% | 21.3% | 26.5%
| | | Other:
| | | Placebo | 20mg | 40mg
| | | --- | 4.2% | 6.2%
| | | Baseline depression assessment:
| | | BDI (mean score):
| | | Placebo | 20 mg | 40 mg
| | | 6.34 | 5.14 | 3.33
| | | Smoking characteristics:
| | | FTND (score);
| | | Placebo | 20 mg | 40 mg
| | | 6.13 | 6.08 | 5.51
| | | Comorbid conditions (n [%]):
| | | History of MDD (%)
| | | Placebo | 20 mg | 40 mg
| | | 17.0% | 22.0% | 22.0%
| | | State-Trait Anxiety (%)
| | | Placebo | 20 mg | 40 mg
| | | 43.69% | 46.29% | 44.50%
Study ID: Vickers, Patten, Lewis, et al., 2009
Geographical location: Rochester, MN Recruitment: Advertisement Setting:; - Mental health, primary care, mixed; - Academic and nonacademic; Veterans clinics: No Study design: RCT Number of participants enrolled: 60 Duration of follow-up: End of treatment = 10 wk Follow-up = 24 wk [underlined: Methods of assessment] Smoking status: Self-reported, 7-day point prevalence abstinence < 8 ppm at end of treatment and urine cotinine at follow-up wk 24 Depression status: HSRD | Intervention description: Tested addition of exercise to NRT in a depressed female population to aid smoking abstinence Intervention: NRT + exercise + smoking cessation behavioral counseling (n = 30) Control: NRT + health education + smoking cessation behavioral counseling (n = 30) Smoking cessation intervention: [underlined: Behavioral interventions] Brief smoking cessation counseling (10 min/visit) with handouts and NCI “Clearing the Air” brochure via same specialist as CBT for exercise [underlined: Drugs] Transdermal patch NRT (21 mg/day) started on quit date (wk 4), continued through wk 10 Depression intervention: [underlined: Behavioral interventions] 10 wk social cognitive theory–informed CBT exercise intervention strategies (not actual exercise) to encourage patient to meet the CDC/ACSM 1995 guidelines of moderate physical activity (30 min/day x 5 wk) via trained (manual and observation) patient education specialist via ten 30 min weekly sessions Topics included benefits, goal setting, reinforcement, problem solving, overcoming barriers, and relapse prevention Exercise activity was self-monitored. [underlined: Comparator intervention(s)] Smoking cessation intervention: [underlined: Behavioral interventions] Same as intervention (above); brief counseling (10 min/visit) with handouts via same specialist as health education [underlined: Drugs:] Same as intervention Depression intervention: [underlined: Behavioral interventions] Equal time/contact control using health education via patient education specialist; topics included sleep, nutrition, preventive screening tests Mean contact time/proportion of sessions completed: Mean (SD) sessions completed out of 10 sessions: | | Inclusion criteria:; - Female; - Ages 18 to 65; - CES-D ≥ 16; - Cigarettes ≥ 10/day for past 6 mo; - Current exercise < 20 min on fewer than 3 day/wk; - Ability to do exercise; - Good health; - Negative pregnancy test; - BMI ≤ 40; Exclusion criteria:; - Recent MI; - Substance abuse; - Psychosis; - Nortriptyline, bupropion; - Other tobacco product use; - Skin allergies or other problems with NRT patch; - Suicidal ideation; Age: Range: 18 to 65 Mean (SD): | | | There were no significant differences between groups on any outcome variable Follow-up rate: Wk 24 follow-up: | | | | | General comments: Subjects were paid a nominal fee: $25 at end of treatment (wk 10) and $25 after follow-up (wk 24) Applicability cautions:; - 65% college-educated; - 100% overweight white females; Study-level quality assessment: Fair to poor Comments:; - Small pilot, not powered for any statistical test stronger than analysis via 2 sample, rank-sum test; - In the exercise literature, not helping [underlined: overweight people with the actual] exercise has been shown to be of no benefit; - Missing outcome data on 50% of sample by wk24; Measure of smoking adequate? Yes Assessment of adverse effects adequate? NR
| | | Treatment | Control | | Treatment | | | Control
| | | 40.9 (11.8) | 41.8 (12.1) | | 16 of 30 (53%) | | | 15 of 30 (50%)
| | | Gender (n [%]): Female 60 (100%) Race/ethnicity (n [%]): White 59 (98%); - Black 1 (2%) in exercise group; - White 30 (100%) in control group; Baseline depression assessment: CES-D, 0–60, > 16 | | | Important baseline differences: Current psychotherapy:
| Treatment | Control | Treatment | Control | | Treatment | | | Control
| 7.6(3.5) | 8.2(2.7) | 29.8(9.3) | 32.4(9.6) | | 7 (23) | | | 11 (37)
| Treatment sequencing: NA Other notes about interventions:; - Important to note that subjects were left on their own to find venues and types of actual exercise; - Also measured weight, weight concerns, change in mood (Positive and Negative Affect Scale), fitness level (VO2 max test), and physical activity (physical activity recall) | | HRSD | | | Current pharmacotherapy
| | | Treatment | Control | | Treatment | | | Control
| | | 12.8(6.0) | 15.4(9.3) | | 16 (53) | | | 19 (63)
| | | Smoking characteristics: | | | [underlined: Outcomes of interest] 1) Abstinences rate: Wk 24 follow-up
| | | Cigarettes/day: | | | Treatment | | | Control
| | | Treatment | Control | | 1 of 16 (6.3%) | | | 1 of 15 (6.7%)
| | | 20.0 (7.8) | 21.6 (7.3) | | 2) Medication adherence rate: NRT:
| | | FTND score ≥ 6 | | | Treatment | | | Control
| | | Treatment | Control | | 36% | | | 31%
| | | 16 (53) | 20 (67) | | Exercise or Education:
| | | Comorbid conditions (n [%]): | | | Treatment | | | Control
| | | None medical or psychiatric; all excluded but examined weight concern: | | | 49% | | | 21%
| | | Treatment | Control | | 3) Differential effects by gender: NA (all female) 4) Differential effects by depression status: NR 5) Differential effects by treatment sequencing: NA Report adverse effects? No
| | | 5.8 (2.2%) | 6.6 (2.1%) | | 3) Differential effects by gender: NA (all female) 4) Differential effects by depression status: NR 5) Differential effects by treatment sequencing: NA Report adverse effects? No
| | | Weight, kg: | | | 3) Differential effects by gender: NA (all female) 4) Differential effects by depression status: NR 5) Differential effects by treatment sequencing: NA Report adverse effects? No
| | | Treatment | Control | | 3) Differential effects by gender: NA (all female) 4) Differential effects by depression status: NR 5) Differential effects by treatment sequencing: NA Report adverse effects? No
| | | 76.0 (15.1%) | 73.6 (15.7%) | | 3) Differential effects by gender: NA (all female) 4) Differential effects by depression status: NR 5) Differential effects by treatment sequencing: NA Report adverse effects? No

Abbreviations: AE = adverse effects, am = ante meridian (before noon), BA = behavioral activation, BATS = behavioral activation treatment for smoking, BDI-II = Beck Depression Inventory-II, BID = two times per day, CBT = cognitive behavioral therapy, CES-D = Center for Epidemiologic Studies-Depression Scale, CI = confidence interval, CO = carbon monoxide, DIS = Diagnostic Interview Schedule, FTND = Fagerstrom Test for Nicotine Dependence, GEE = generalized estimating equation, HDRS = Hamilton Depression Rating Scale, ID = identification, ITT = intention to treat, MDD = major depressive disorder, MDE = major depressive episode, mg = milligram or milligrams, ml = milliliter, mo = month/months, n = number, NA = not applicable, NCI = National Cancer Institute, ng = nanogram, NR = not reported, NRT = nicotine replacement therapy, ns = not significant, OR = odds ratio, p = probability, pm = post meridian (afternoon), POMS = Profile of Mood States, ppm = parts per million, RCT = randomized controlled trial, SCID = Structured Clinical Interview for DSM Diagnoses, SD = standard deviation, SE = standard error, ST = standard treatment, UDD = unipolar depressive disorder, vs = versus, wk = week/weeks, yr = year/years

## LIST OF INCLUDED STUDIES IN ALPHABETICAL ORDER

Brown RA, Kahler CW, Niaura R, et al. Cognitive-behavioral treatment for depression in smoking cessation. J Consult Clin Psychol. 2001;69(3):471-80. [pmid: 11495176].
Covey LS, Glassman AH, Stetner F. Naltrexone effects on short-term and long-term smoking cessation. J Addict Dis. 1999;18(1):31-40. [pmid: 10234561].
Covey LS, Glassman AH, Stetner F, et al. A randomized trial of sertraline as a cessation aid for smokers with a history of major depression. Am J Psychiatry. 2002;159(10):1731-7. [pmid: 12359680].
Duffy SA, Ronis DL, Valenstein M, et al. A tailored smoking, alcohol, and depression intervention for head and neck cancer patients. Cancer Epidemiol Biomarkers Prev. 2006;15(11):2203-8. [pmid: 17119047].
Evins AE, Culhane MA, Alpert JE, et al. A controlled trial of bupropion added to nicotine patch and behavioral therapy for smoking cessation in adults with unipolar depressive disorders. J Clin Psychopharmacol. 2008;28(6):660-6. [pmid: 19011435].
Hall SM, Munoz RF, Reus VI. Cognitive-behavioral intervention increases abstinence rates for depressive-history smokers. J Consult Clin Psychol. 1994;62(1):141-6. [pmid: 8034816].
Hall SM, Munoz RF, Reus VI, et al. Mood management and nicotine gum in smoking treatment: a therapeutic contact and placebo-controlled study. J Consult Clin Psychol. 1996;64(5):1003-9. [pmid: 8916629].
Hall SM, Reus VI, Munoz RF, et al. Nortriptyline and cognitive-behavioral therapy in the treatment of cigarette smoking. Arch Gen Psychiatry. 1998;55(8):683-90. [pmid: 9707377].
Hall SM, Tsoh JY, Prochaska JJ, et al. Treatment for cigarette smoking among depressed mental health outpatients: a randomized clinical trial. Am J Public Health. 2006;96(10):1808-14. [pmid: 17008577].
Hayford KE, Patten CA, Rummans TA, et al. Efficacy of bupropion for smoking cessation in smokers with a former history of major depression or alcoholism. Br J Psychiatry. 1999;174:173-8. [pmid: 10211174].
Kinnunen T, Doherty K, Militello FS, et al. Depression and smoking cessation: characteristics of depressed smokers and effects of nicotine replacement. J Consult Clin Psychol. 1996;64(4):791-8. [pmid: 8803370].
Kinnunen T, Korhonen T, Garvey AJ. Role of nicotine gum and pretreatment depressive symptoms in smoking cessation: twelve-month results of a randomized placebo controlled trial. Int J Psychiatry Med. 2008;38(3):373-89. [pmid: 19069579].
MacPherson L, Tull MT, Matusiewicz AK, et al. Randomized controlled trial of behavioral activation smoking cessation treatment for smokers with elevated depressive symptoms. J Consult Clin Psychol. 2010;78(1):55-61. [pmid: 20099950].
Munoz RF, Marin BV, Posner SF, et al. Mood management mail intervention increases abstinence rates for Spanish-speaking Latino smokers. Am J Community Psychol. 1997;25(3):325-43. [pmid: 9332966].
Saules KK, Schuh LM, Arfken CL, et al. Double-blind placebo-controlled trial of fluoxetine in smoking cessation treatment including nicotine patch and cognitive-behavioral group therapy. Am J Addict. 2004;13(5):438-46. [pmid: 15764422].
Vickers KS, Patten CA, Lewis BA, et al. Feasibility of an exercise counseling intervention for depressed women smokers. Nicotine Tob Res. 2009;11(8):985-95. [pmid: 19541948].