# REVIEWER COMMENTS AND RESPONSES

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes – no comment | Thank you.
2 | Yes – excellent review and very clearly written | Thank you.
3 | The selection of appropriate outcome measures warrants more attention on p 14 or p 17 line 8. See the Hughes et al 2003 report of recommendations of the abstinence outcome measures work- group of the Society for Research on Nicotine and Tobacco (Hughes J. R., Keely J. P., Niaura R. S., Ossip-Klein D. J., Richmond R. L., Swan G. E. Measures of abstinence in clinical trials: issues and recommendations. Nicotine Tob Res 2003; 5: 13–25). | We have further clarified outcome measures in the methods section. Operationalization of smoking cessation was informed by those used in Cochrane reviews of smoking cessation which is based on the Russel Standard (West R, Hajek P, Stead L, Stapleton J. Outcome criteria in smoking cessation trials: proposal for a common standard. Addiction 2005;100(3):299–303).
3 | The availability of biological verification of self-report (CO or cotinine) in only a couple of studies should also be noted as a limitation in this literature. | All included studies use biological verification of self-report smoking cessation.
3 | The systematic search strategy is among the many strengths of the review. It may be implicit in the MESH term “smoking”, but it would be worth indicating on p 13 and/or in Appendix A that “nicotine” and “tobacco” are subsumed in that category. Tobacco currently only appears under PsycINFO. | “Tobacco” and “nicotine” are not indexed under the MESH term “smoking.” Adding these terms yields an additional 81 articles of which none met our eligibility criteria.
4 | Yes – no comment | Thank you.
5 | Yes – no comment | Thank you.
6 | Yes - Thanks for the opportunity to see this work. The key questions are succinctly and clearly defined in logical sequence. Language is clear and concise. Figure 1 page 13 is helpful. In general I think this review has been well conducted and well summarized. | Thank you.
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No–no comment | Thank you.
2 | P 25 lines 22–23----check numbers | Numbers are correct.
2 | P 27 line 11----it would be easier for the reader if you consistently describe the comparisons being made. For example, it would be a lot easier to grasp this if the subtitle was: “Antidepressant therapy +cotreatment versus placebo +co-treatment” rather than how it is written. Same issue occurs again in line 15---I would switch “antidepressants” and “behavioral” | We agree and have made the changes requested.
2 | P 29 line 15 table 7----add in risk estimates | Comparisons nonsignificant and risk estimates not reported.
3 | No - Comments: The report appears to be rigorously objective. | Thank you.
4 | No–no comment | Acknowledged
5 | No–no comment | Acknowledged
6 | Possibly - Search: Limiting the search to English Language only will introduce bias, as will limiting the search to only the peer reviewed literature (publication bias). There may be other important trials in progress. | Non-English language articles are beyond the scope of this review. Inclusion of non–peer reviewed literature is controversial as these reports are often incomplete and can differ from final peer reviewed publication. An advantage of non-peer reviewed literature is a greater ability to detect publication bias. For this review, we thought the potential negatives of included these types of reports outweighed the potential advantages.
6 | Page 4: when referring to small positive effects of trials it is unclear whether these are statistically or clinically important differences? Did they “show” effects? Or simply “suggest” effects? Or just “trends” that could be due to chance. Could the wording here be tightened so this is clearer? | We have added greater specificity to the language.
6 | Page14: it is unclear why hospital based interventions were excluded? If seeking to include trials of people with current depressive symptoms, then an inpatient setting might capture some of these? (key question 2) Ditto the exclusion of relapse prevention trials may have excluded some direct or indirect evidence of efficacy of sequential treatment strategies (key question 4) | Stakeholders interested in outpatients and smoking cessation. However, we agree that including studies of relapse prevention could yield some indirect evidence but we thought that this would be too indirect for our purposes in this review.
Question 3: Are there any studies on of interest to the VA that we have overlooked?
1 | NO- no comment | Acknowledged
2 | No–no comment | Acknowledged
3 | The following study by McClure et al. appears to meet the criteria in Table 1 and is of particular interest to VHA given the focus on varenicline. If there is a reason for exclusion it would be important to clarify and there would still appear to be value in addressing the findings as they relate to KQ5 since there is currently no mention of varenicline in the document. McClure JB, Swan GE, Jack L, Catz SL, Zbikowski SM, McAfee TA, Deprey M, Richards J, Javitz H., Mood, side-effects and smoking outcomes among persons with and without probable lifetime depression taking varenicline. J Gen Intern Med. 2009 May;24(5):563–9. Epub 2009 Feb 24. | We identified and excluded McClure study because report did not provide data on rates of smoking cessation for the depressed subgroup by intervention arm. Therefore, we could not include these data in our analysis of the comparative effectiveness of smoking cessation interventions for depressed patients.
3 | Two recent qualitative reviews also seem worth citing in the background: Hitsman B, Moss TG, Montoya ID, George TP. Treatment of tobacco dependence in mental health and addictive disorders. Can J Psychiatry. 2009 Jun;54(6):368–78. Review. Hall SM. Nicotine interventions with comorbid populations. Am J Prev Med. 2007 Dec;33(6 Suppl):S406–13. | Thank you for this suggestion. We have added these to the background section.
4 | No–no comment | Acknowledged
5 | No–no comment | Acknowledged
6 | Excluding evidence based on timing of outcome reporting: figure 2 page 20. I have trouble reconciling what I read in the report results with what is detailed about trial flow in figure 2. Figure 2 suggests trials were excluded based on their choice of outcomes, or their choice of outcome reporting timepoint post intervention. In general terms, excluding evidence on the basis of outcomes is not recommended, if the trials otherwise meet inclusion criteria (population, design, intervention). For the 6 articles that reported outcomes of interest, but not at 6 and 12 months, it is possible that useful data do exist – but not in the published reports. Some description of these trials and their data might be informative, even if they are not subsequently able to contribute to predefined meta-analyses, or be used to inform the evidence summary. This is also true for the 14 articles that did not report the outcome of interest in their publications but otherwise met inclusion criteria (design, population, intervention) – perhaps the outcome data you sought does exist, and might be available from investigators. | As we described, few (n = 3) of the studies enrolled patients with depressive symptoms. Most included studies are secondary analysis, using history of depression. The studies excluded typically report smoking cessation outcomes, but not in the subgroup of interest (those with depression) and many are small without the power to evaluate interaction effects between depression and smoking cessation interventions. Also 6- and 12-month outcomes are clinically relevant. Contacting the authors for additional data is beyond the scope of these reviews. However, we’ve raised the possibility of missing studies with unpublished but relevant outcomes.
6 | In summarizing evidence, and if making suggestions for a future research agenda, then acknowledging these additional trials might be helpful: rather than undertaking new trials, considering making better use of existing data is also important. This can take the form of secondary analyses of existing trial data, or attempting individual patient data meta-analysis | The suggestions for patient level meta-analysis or secondary analysis of existing trial data has been incorporated into possibilities for future research.
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | Comments were about the topic in general and not the report. | OK
2 | P1 line 5---add prevalence | We added prevalence.
2 | P3 line 12---do you include chantix? | Yes, but no trials using this drug met our eligibility criteria.
2 | P4 line 15---clarify what the antidepressant trials are compared to | We have clarified in text.
2 | P 5 line 10---clarify: does “control condition” belong in this sentence | Yes it does.
2 | P 6 line 6---I would rephrase this “…does treatment effectiveness differ by whether smoking cessation/depression treatments are delivered concurrently or sequentially?” | We have made this change.
2 | P 8 line 12----“for adding behavioral mood management counseling to____what? | We have clarified in text.
2 | P 10 line 14–16---clarify the sequential/concurrent text. perhaps add an example on line 16. “…depression. For example….” | We have clarified in text.
2 | P 10 line 12 ----might add sentence after “sequentially” that says, “It is plausible but unstudied” if this is true. | We have added this sentence.
2 | P 19 line 7---? Manually pulled? You might rephrase this | We have rephrased this sentence.
2 | P 21 table 3---I think you should try and fit this on one page and definitely should add the setting to this table. Please also define FTND | We have modified table and “FTND” is defined in the footnotes of Table 3.
2 | P 27 line 22 table---note it should be “approach” not “approached”. It would be nice to include a summary estimate in this table as well as many of the others also. | We have made this change and include summary estimates in the text, when available, for the comparisons of interest, smokers with depression by intervention arm.
2 | P 28 line 10---switch antidepressant and behavioral to make the comparisons clearer | We have changed all the title to make this clearer.
2 | P 29 line 15 table 7---add in risk estimates | We include risk estimates in the text, when available, for the comparisons of interest, smokers with depression by intervention arm.
2 | P 29, line 23---clarify what active control is | We have added example of active control.
2 | p 32 line 9 use “at” rather than “of” | We have made this change.
2 | Table 9---risk estimates would be helpful | We include risk estimates in the text, when available, for the comparisons of interest, smokers with depression.
2 | 39 line 18---intervention rather than “interventions” | We have made this change.
2 | P 40. I would move the full sentence beginning in line 11–12 to the beginning of the paragraph | We respectfully disagree. This sentence belongs in the paragraph about mood management treatments.
2 | P 44 line 19----??? “can make”???? | We have clarified the language.
3 | Varenicline is not mentioned in the document. Perhaps the basis for the McClure et al (2009) trial analysis was not evident to me for KQs 1–4, but the data on adverse effects seem highly relevant to Key Question 5 and use of varenicline for patients with MH diagnoses is of high interest within VHA, including recently revised criteria for use that emphasize psychiatric stability. | We did not exclude trials that used varenicline. No trials using varenicline met our eligibility criteria. Therefore, it is beyond the scope of this report to discuss adverse effects for therapies not included in included trials. We, however, now briefly discuss use of varenicline for veteran with mental health issues in the discussion section.
3 | The report should be more explicit in distinguishing history of depression from current depression that met diagnostic criteria and from current depression symptoms based on exceeding assessment thresholds. The identified language convention in p 23 line 11–13 does not seem to be applied consistently and it combines current depressive symptoms with current depression diagnosis. Similarly, on P 3 line 21– among 3 studies that recruited participants with current depression, did some require that participants meet diagnostic criteria and others use assessments in the absence of diagnoses? Other statements to clarify history vs. current vs. either are p 25 line 7; p 29 line 23, p 30 line 6, p 30 line 11, p 31 line 20, p 40 line 14, Table 10 footnote b. Consider adding a footnote to Table 3 to designate the distinct meanings of current depression. | The reviewer is correct that we combined current and history- positive studies. As outlined in our research questions, we assessed the comparative effectiveness of smoking cessation strategies of patients with a history of a depressive disorder or current significant depressive symptoms. We, however, planned a priori to conduct subgroup analyses by depression status but were unable to do so due to low number of studies per comparison. We note this as a limitation of our study We state the method of depression assessment for the three studies that recruited participants with current depression or elevated depressive symptoms on page 23 lines 9–12. We have clarified footnote b of table 10.
3 | Regarding Key Question 2, the dimension at issue appears to be recency (i.e., history vs. current) or “type” (p 42 lines 19–20). Severity per se can vary widely among those classified as currently depressed, but this was not reflected in analyses. | For Key Question 2, we were interested in depression status at time entering trial. This could be operationalized as type or symptom severity at study entry. No studies conducted subgroup or interaction effects based on symptom severity at study entry. Therefore, we only reported on two studies that identified results based on depression type. For Key Question 2, we clarify that we were interested in depression status at study entry throughout the revised report. We intended to conduct subgroup analysis by depression status but number of studies was too few.
3 | RR is a conventional way to report trial outcomes, however to increase clinical relevance of effect sizes it would be helpful to report NNT or to advocate that this be included in future reports. For the Discussion, consider quantifying effects with NNT where possible (e.g., p 40 line 11). | According to the Cochrane Handbook, NNT cannot be combined for a summary estimate in meta-analysis. We, therefore use RR for our analyses. We, however, have computed a NNT for our significant summary effect for the addition of mood management treatments.
3 | As noted in the Discussion, most subgroup analyses warrant cautious interpretation. A recent reference at p 43 line 11 would help to emphasize that point (e.g., Sun X, Briel M, Walter SD, Guyatt GH. Is a subgroup effect believable? Updating criteria to evaluate the credibility of subgroup analyses. BMJ. 2010 Mar 30;340 doi: 10.1136/bmj.c117). It would also be useful to identify subgroup analyses reported in the selected studies as a priori or post hoc (e.g., p 5 line 20). | Thank you for the citation. We have added this to the report. Also studies did not state that subgroup analyses were conducted a priori and, thus, powered to detect interaction effects. We noted this as a limitation.
3 | Most of the studies excluded patients with current/recent substance use or substance use disorders. Given the high comorbidity of alcohol and other substance use disorders with smoking and depression, this is a limitation to generalizability worth noting. | We have added this as a limitation.
3 | There is evidence in the broader literature about the role of combination pharmacotherapy (e.g., combination NRT; see Shah SD, Wilken LA, Winkler SR, Lin SJ. Review and meta- analysis of combination therapy for smoking cessation. J Am Pharm Assoc (2003). 2008 Sep– Oct;48(5):659–65.) and this has resulted in guidance through VA Pharmacy Benefits (PBM-MAP Recommendations for Use of Combination Therapy in Tobacco Use Cessation; http://www.pbm.va.gov or http://vaww.pbm.va.gov) . This is an important area for future research on those with depression and is worth identifying in the Discussion and considering for the Executive Summary on p 7. This could also be cited on p 10 line 3 in the context of individual forms of NRT. P 39 line 20 should specify that the 4 trials involved single forms of NRT and none involved combinations. P 41 para 2 and p 46 last full sentence are other locations to raise this point. | We agree and stated this in our discussion of future research in and in the executive summary that combination therapies are an important area of future study. We have expanded this section and added VA PBM-specific information per the reviewer’s suggestion. We also have clarified that the NRT trials are single-form NRT trials.
3 | KQ4 has high clinical relevance. Despite the absence of systematic analyses that address this issue, it would be useful to comment on whether/how current depression was addressed (e.g., with concurrent anti-depressants or psychotherapy) other than in conditions that involved mood management or bupropion, etc., and whether any anti-depressant doses were in the therapeutic range for treatment of depression (e.g., p 40 para 3). It seems important to comment on whether the evidence better addresses effects of smoking cessation in the context of treatment resistant depression or untreated depression (e.g., p 41 para 2 or p 42 para 2). The guidance on p 44 para 2 seems to suggest that behavioral mood management and NRT are adequate in the context of unresolved/untreated depression rather than encouraging concurrent patient engagement in guideline concordant care to address the depression. Note the contrast with the example on p 46 para 2 and p 47 first full sentence. | All but a few studies included in this report excluded MDD positive patients. Most patients included in this report could only be categorized as symptom positive, with no information on treatment resistance in the original papers. Therefore, we cannot comment on the effects of these smoking cessation strategies on patients with treatment resistant depression. Also we have clarified that we refer to the effects of antidepressants on smoking cessation. We were able to assess that antidepressant doses were in the therapeutic range. We have added this level of detail to the report.
3 | As noted on p 47, differential effects of mode of therapy could not be answered with available data. Since the issue of group vs. individual behavioral interventions has high relevance to implementation feasibility, it seems worth noting in regard to the heterogeneity of treatment categories (p 42 line 8). Uncertainty about advantages of individual vs. group modality for mood management (p 44 line 11) also would be useful to clarify. | We have added this clarification.
3 | Table 3–recheck sample description for Duffy; p 63 indicated 69% with current depression? | Our numbers are correct. In Duffy et al., 69% of the total sample had depression but only 35% (n = 64) had comorbid depression and smoking at baseline.
4 | In general, this report is thorough, well-written and objective. The reader gains a great deal of knowledge from the review of studies. Several specific comments are provided below. With the exception of the comment about exclusion of studies relating to Figure 2 on page 20, most of these comments are relatively trivial, but attention to them may slightly strengthen the review. | Thank you.
4 | On page 10, line 20, the meaning of the following sentence is a bit opaque. This sentence could perhaps be eliminated or rewritten: “Yet the extent to which level of depressive symptoms affects smoking cessation efforts has not yet been synthesized.” | We agree and have deleted this sentence.
4 | On page 10, line 23 (going onto page 11), the sentence, “Treating depression first may lead to greater treatment adherence and, consequently, better cessation rates” while having face validity, represents speculation, and that point should be made clear here. | We agree and have clarified that this is plausible but not yet known.
4 | On page 11, line 2, likewise the sentence, “Smokers with psychiatric comorbidities may benefit from combined behavioral counseling and 3 pharmacotherapy with longer therapeutic smoking cessation approaches (i.e., exceeding 8 to 12 4 weeks) to reduce likelihood of dropout and depression relapse” while a reasonable supposition actually poses a hypothesis to be examined, but the language here does not make that point entirely clear. | The original language does not state this as a known. Our language states that these approaches may be beneficial. We then state that this needs to be studied.
4 | Page 14, line 10, Table 1: The exclusion for relapse prevention as an outcome is not entirely graspable. Does it mean that studies which randomized participants who had already quit and evaluated relapse as an outcome were excluded? If so, try to make this point clearer perhaps via an additional footnote. | We have added a footnote that defines relapse prevention.
4 | Page 20, Figure 2: 6 studies were excluded because the “Main outcome not reported at desired interval.” However, the report gives no justification for the outcome intervals selected (self-reported 7 day abstinence at 6–12 months or [secondarily] abstinence at 3–4 months.) Considering that only 16 RCTs were ultimately included in the analysis, there must be more justification for the exclusion of 6 potential studies simply on the basis of outcome interval when we really do not know the optimal interval for testing abstinence that might predict long term quitting. | We have further clarified outcome measures in the methods section. Operationalization of smoking cessation was informed by those used in Cochrane reviews of smoking cessation which is based on the Russel Standard (West R, Hajek P, Stead L, Stapleton J. Outcome criteria in smoking cessation trials: proposal for a common standard. Addiction 2005;100(3):299–303). Also, the six excluded studies reported outcomes at end of treatment. End of treatment is not likely to be a good indicator of long-term smoking cessation.
4 | Page 24, line 11, “antidepressants” should be singular “antidepressant.” | We have made this change.
4 | Page 24, lines 15–16, oral naltrexone should not be called “long acting.” The parent drug has an average half-life of 4 hours, the active metabolite an average half-life of 12 hours. The way it is described here, it could be confused with the long acting injectable naltrexone which has therapeutic effects lasting 28 days. | The original paper refers to the naltrexone used in the study as “long acting.” We have clarified that the trial used the pill form of naltrexone.
4 | Page 27, line 22, Table 6, second and third columns, second row, change “approached” to “approach.” | We have made this change.
4 | Page 30, line 4, consider rewording the sentence, “Overall, we did not find enough evidence to support adding antidepressants to other smoking cessation cotreatments for persons with depression.” Most of the studies looked at participants with prior histories of depression. If the patient has current depression and is trying to quit, most likely we would want her/him on an antidepressant for its effects on depression regardless of its lack of effect for smoking cessation. The wording as is could leave the impression that these patients should not be on antidepressants at all. | Our primary outcome of interest was smoking cessation. Therefore, we were interested if adding antidepressants to smoking cessation cotreatments improves smoking cessation outcomes. It is an empirical question if persons with current depression undergoing a quit attempt receive relief from their depression with antidepressants therapy alone versus psychotherapy or combination psychotherapy and pharmacotherapy for depression. We, however, have reworded the sentence so that it is clear we are referring to antidepressant effects on smoking cessation alone.
4 | Page 35, line 7, rewrite sentence, “Participants were randomized to 12 weeks of bupropion plus a cotreatment consisting of 8 weeks of transdermal NRT and 13 sessions of group CBT smoking cessation counseling or cotreatment plus placebo.” One potential suggestion is: “Participants were randomized to 12 weeks of bupropion vs. placebo. Both groups received a cotreatment consisting of 8 weeks of transdermal NRT and 13 sessions of group CBT smoking cessation counseling. | We have changed the wording per the reviewer’s suggestion.
4 | Page 35, line 9 creates some confusion by saying “Among participants who were history positive for unipolar depression . . .” Whereas, earlier on line 6, the text indicates that “Evins (2008) recruited 199 smokers who were history positive for unipolar depressive disorders.” The text in line 9 makes it sound like all subjects were not history positive, but line 6 indicates that they were. It appears that the entire paragraph beginning on line 6 needs reworking. | We have revised the paragraph in order to better explain that Evins (2008) recruited participants with lifetime histories of unipolar depression but then assessed cessation rates by current versus history-positive groups.
4 | Page 36, lines 2–8, the differences in n’s between men and women and the overall small sample size really preclude drawing any conclusions from these data. Please either supply the quit rates for men or comment that the small samples sizes render the study very inconclusive. A general caveat about this type of finding which occurs in other areas of the review appears on page 43, lines 5–1, but it also may be helpful to include such caveats in the specific areas of the report they pertain to. This strategy introduces redundancy but may aid clarity. | We agree with the reviewer that the small number of participants limits our ability to draw any conclusion. We state this as a global limitation of many of our findings. The study did not report quit rates for men beyond end of treatment assessments.
4 | Page 38, Table 10, if possible it would be good add a column listing the interventions. The interventions are listed in other tables, but it is difficult for the reader to flip back and forth. The clinical meaning of the adverse events is not too apparent if the reader is unsure of the intervention possibly related to the adverse events. | We have added a column describing the interventions.
4 | Page 40, lines 1–4, the wording here could give the reader the impression that the interventions mentioned are inefficacious, when, in fact, they have been insufficiently studied. An attempt to make that clear via the final clause in the paragraph does not quite get there. This point should be explicitly stated. | We have clarified that these are understudied strategies that need further examination.
4 | Page 40, line 6, the sentence, “Smokers with depression are more likely to have increased levels of negative precessation and postcessation” is poorly phrased. How about, “Smokers with depression are more likely to have increased levels of negative mood both pre- and post-cessation.” | We have made this word change.
4 | Page 41, line 13, remove word “elevated.” | We removed this word.
4 | Page 44, line 19, the sentence, “Smokers with depression can make and maintain smoking cessation” is a little awkward and would benefit from rewording. | We have reworded this sentence.
5 | Overall, I found the report extremely clear and well-written. I learned a lot from the content, particularly how seldom this important topic has been adequately studied. | Thank you.
5 | Page 7, lines 11–14–Which category would varenicline fit into? Also, I think it matters whether the antidepressant being studied is bupropion or nortriptylline (both endorsed by the PHS guidelines) vs. the other antidepressants. On the other hand, none of the antidepressant studies really showed much, so maybe it is not necessary to separate them out. | We had insufficient number of trials to assess antidepressant effects by specific drug. We state this as a limitation.
5 | Page 38–I would change the heading for Column 2 in Table 10 to “…%reported in intervention versus control)”. The way it reads now, it appears that the control group was much more likely to experience many adverse effects, particularly in Hall, 1998. It was only after a few minutes that I noticed footnote c indicating that the intervention group experienced more. So, I would keep the footnote but also have the order in the column heading consistent with the order reported in each row. | We agree and have made this change.
6 | Page 23: It would be informative to have details of the disaggregated quality criteria scores for the included trials. As provided, I am not able to judge how trials scoring “fair” differed from those scoring “good”. This would be best within the main body, but could be included in an appendix. Without these details, the transparency of the review is compromised, and the leap to GRADE in table 11 not clear. | We followed guidance in the EPC CER methods manual to report summary quality scores.
6 | Funnel plots are uninformative and unhelpful when there are small numbers of trials. In addition, the review has excluded any trials not published in peer reviewed journals, making the rationale for funnel plots questionable. Thus, appendix D would be better removed. | We agree. The funnel plots were presented in the draft review for completeness but have been removed from the final review
6 | In forest plot figures, displaying the outcome number (eg figure 3, 1.2.1) is confusing to the reader. These should be removed from the plots. | This has been corrected.
6 | In forest plots with only 1 stratum of trials, please remove the bottom summary estimate – it merely duplicates the stratum summary estimate, complicates the plots and potentially confuses readers (eg figure–3 remove “total”– it is same as “subtotal” estimate) | This has been corrected.
6 | In forest plots, it is helpful to order trials by the weight they contribute to the meta analysis – thus making in easier to see which trial contributes most to the summary estimate of effect, and also which are likely to be responsible for any heterogeneity. | We have made this change.
6 | Consistency of style and content among tables: table 9 page 34 includes a column marked “rating”, with no further explanation. Presumably this reflects methodological quality? Similar tables preceding and following do not contain this column. | We have deleted this column.
6 | The evidence tables page 57 onwards are enormous and somewhat unwieldy. It is hard to see where one trial stops and another starts. Could these be reorganised so there is clearer delineation among trials? Certainly start each new trial at the top of a page, even separate table for each trial? | We have disaggregated the evidence tables. Each table starts on a new page.