# SEARCH STRATEGY

[underlined: PubMed:] Search on March 10, 2010 (yield = 463 articles)

((“smoking cessation”[MeSH Terms] OR (“smoking”[All Fields] AND “cessation”[All Fields]) OR “smoking cessation”[All Fields]) OR (“Smoking/prevention and control”[Mesh:noexp] OR “Smoking/therapy”[Mesh:noexp])) AND (“Depression”[Mesh] OR ((“Depressive Disorder”[Mesh:noexp] OR “Depressive Disorder, Major”[Mesh]) OR “Dysthymic Disorder”[Mesh]))

[underlined: Embase:] Search on March 10, 2010 (yield = 489)

‘depression’/de OR ‘agitated depression’/exp OR ‘atypical depression’/exp OR ‘depressive psychosis’/exp OR ‘dysphoria’/exp OR ‘dysthymia’/exp OR ‘endogenous depression’/exp OR ‘major depression’/exp OR ‘masked depression’/exp OR ‘melancholia’/exp OR ‘mixed anxiety and depression’/exp OR ‘mixed depression and dementia’/exp OR ‘mourning syndrome’/exp OR ‘organic depression’/exp OR ‘reactive depression’/exp OR ‘recurrent brief depression’/exp AND (‘smoking cessation’/exp/mj OR ‘smoking cessation program’/exp/mj)

[underlined: PsycINFO:] Search on March 10, 2010 (yield = 219)

(DE “Depression (Emotion)”) or (DE “Major Depression” or DE “Affective Disorders” or DE “Anaclitic Depression” or DE “Dysthymic Disorder” or DE “Endogenous Depression” or DE “Reactive Depression” or DE “Recurrent Depression” or DE “Treatment Resistant Depression”) and ((“Smoking Cessation” or (DE “Drug Rehabilitation”) and (DE “Tobacco Smoking”))

[underlined: Cochrane Library:] Search on March 10, 2010 (yield = 169)

Smoking cessation and depression (limit clinical trials)