# SUMMARY AND DISCUSSION

A key observation that emerges from this review is that integration of care for the purpose of improving general medical outcomes in individuals with SMI is an understudied area, with only four RCTs meeting our study criteria. Further, these studies tested a limited range of approaches to integrating care. Despite these limitations, these four studies provided useful findings for several of our key questions. These findings and the overall strength of evidence are summarized and discussed by key question.

## SUMMARY OF EVIDENCE BY KEY QUESTION

Table 10 Strength of evidence by key question

Key question | Strength of evidence | Summary
KQ 1. What types of care models have been evaluated prospectively that integrate mental health care and primary medical care with the goal of improving general medical outcomes for individuals with serious mental illness (SMI)? | Not relevant to KQ 1 | 4 good-quality studies Conclusions:; - The degree of integration of care ranged from limited to moderate.; - The range of integrated care models tested was relatively limited. Many PCMH elements were not included in tested models.; - A broader range of disciplines should be included in future evaluations of integrated care models.
KQ 2. Do models of integrated care for individuals with SMI improve the process of care for preventive services (e.g., colorectal cancer screening) and chronic disease management (e.g., annual eye examination in patients with diabetes mellitus [DM])? | Moderate | 2 good-quality studies Conclusions:; - Studies showed generally positive effects on immunization rates, cancer screening, and selected screening for cardiovascular disease.; - Important cancer-screening practices (e.g., mammography, pap smears) and chronic disease care unrelated to cardiovascular disease were not studied.
KQ 3. (3a) Do models of integrated care for individuals with SMI improve general functional status outcomes (e.g., as measured by SF-36) or disease-specific functional status outcomes (e.g., Seattle Angina Questionnaire) related to medical care for chronic medical conditions such as DM, hypertension, or heart failure? (3b) Do models of integrated care for individuals with SMI improve clinical outcomes related to preventive services (e.g., influenza rates) and chronic medical care (e.g., kidney disease, amputations, retinopathy in patients with coexisting DM)? | Moderate for KQ 3a Insufficient for KQ 3b | 4 good-quality studies for KQ 3a; no studies reported data relevant to KQ 3b Conclusions:; - Studies reported inconsistent effects on physical functional status. Two studies showed small, positive effects, and two showed no statistically or clinically significant benefit.; - No study reported effects on disease-specific functional status or clinical outcomes.
KQ 4. What are the gaps in evidence for determining how best to integrate care to improve general medical outcomes for individuals with SMI? | Not relevant to KQ 4 | 4 good-quality studies Conclusions:; - There was little diversity in the types of models tested, with most models based on Wagner’s Chronic Care Model.; - Elements of PCMH, other than those that overlap with the chronic care model, were not generally evaluated.; - Other than cardiovascular disease, greater variety of chronic disease outcomes is missing in the literature.; - There was relatively little evidence regarding individuals with schizophrenia and related psychotic disorders.

Abbreviation: DM = diabetes mellitus; KQ = key question; PCMH = patient-centered medical home; SF = Short Form; SMI = serious mental illness

### KQ 1

For KQ 1, four RCTs (represented by seven articles) evaluated approaches to integrated care and most commonly were theoretically based on the chronic care model. All integrated care models were set in mental health specialty settings, had additional personnel, and used care management or care coordination as a key strategy. Only one study used co-located mental health and general medical services. Self-management support was a component in three of the four studies, but only one study used decision support for general medical care.

Within VHA, general medical and psychiatric services are most often provided in settings that are organizationally and geographically distinct. Integrating these services for patients with SMI has the potential to improve outcomes. At the simplest level, the integration of mental and physical health care takes place when specialty mental health and general medical providers collaborate to address the mental and physical health needs of their patients. Broadly speaking, integration can occur in two ways: specialty mental health care being introduced into general medical settings or general medical care being introduced into specialty mental health settings. A robust literature shows that integrating mental health services into primary care improves mental health outcomes. In contrast, few trials have tested approaches to integrating care to improve general medical outcomes for patients with SMI. On the spectrum of limited integration (e.g., communication between providers) to fully integrated (e.g., shared development and implementation of the treatment plan), the interventions tested range from limited55,56,58 to moderately integrated.60

Although these interventions have been informed by the chronic care model, elements such as decision support, shared decisionmaking, self-management support related to chronic medical conditions, and community linkages have not been commonly included. If the conceptual model were broadened to include elements of PCMH, then additional elements such as designated care teams, shared medical appointments, home telemonitoring, test and referral tracking, and performance monitoring might be tested. Implementing the PCMH in VHA—known as the Patient Aligned Care Team (PACT)—provides a potential opportunity to test these models for individuals with SMI. The locus of care for such a model for individuals with SMI is yet to be determined. The studies identified maintained mental health settings as the central point of care with services either augmented in these settings by co-located general medical services, or by placing care managers in the mental health setting to facilitate care in the general medical setting. Given the intensity of psychiatric services often required and provided in this population, this may be a logical approach; however, studies where psychiatric services were provided to augment general medical services in the general medical setting were not identified. It is possible that the general medical and mental health needs of some individuals with SMI can be adequately provided within the context of PACT, but this model of care has not yet been formally evaluated. Finally, by emphasizing the team-care approach essential to PACT, these models could test multidisciplinary teams that include nutritionists and psychologists or health educators to address needed behavior changes. Consistent with the transformation of VA mental health services towards a recovery orientation, peer support interventions may also be useful, with one pilot study showing benefit for patient activation and number of primary care visits in a study of veterans with SMI.74

Another potential strategy that does not appear to have been studied is the training of mental health professionals to directly manage some common general medical illnesses. It is possible that this strategy could improve general medical outcomes in individuals with SMI without increasing the burden on primary care services. However, interventions that attempt to improve mental health care through training primary care providers have been largely ineffective.

### KQ 2

Two good-quality trials involving 527 patients reported outcomes relevant to KQ 2. These studies showed generally positive effects on immunization rates, cancer screening, and selected screening for cardiovascular disease. We rated the strength of evidence for these outcomes as moderate. However, important cancer-screening practices (e.g., mammography, pap smears) and chronic disease care unrelated to cardiovascular disease were not studied.

When examined in detail, these studies showed important differences in intervention design, with Druss and colleagues (2001)60 co-locating primary care services in the mental health setting in a VA medical center and Druss and colleagues (2010)54 providing care management in an urban community mental health center to facilitate care with various primary care providers in the community. In the later study, primary care providers were organizationally and physically separate from the community mental health center. These studies provide evidence that integrated care models can improve preventive services and chronic disease management as compared with usual care—one in an integrated system and one in a nonintegrated system. Both studies included a broad range of individuals with SMI. Given the theoretical reasons, as shown in our analytic framework, for differential effects by specific mental illnesses, social support systems, and severity of chronic medical illnesses, larger studies in multiple sites would be helpful to further understand the impact of integrated care models on these outcomes for individuals with SMI.

### KQ 3

For KQ 3, four good-quality trials reported inconsistent effects on physical components of functional status. Two studies showed small, positive effects, and two showed no statistically or clinically significant benefit. We rated the strength of evidence for the finding of no to small positive effects on physical functioning as “moderate.” No study reported disease-specific functional status or clinical outcomes. We rated the strength of evidence “insufficient” for these outcomes.

Integrated care models, ranging from limited to moderate levels of integration, had inconsistent effects on the physical component of functional status for individuals with SMI. Additional studies may help to clarify these mixed results. Interventions that are more tailored to specific disease states, or utilize greater levels of integration and organizational support may be required to produce more robust effects on functional status. That there were no studies providing data on clinical outcomes, such as disease-specific or all-cause mortality rates, is a significant gap in the literature. However, numerous studies among the general population have demonstrated strong links between process measures for prevention and chronic disease management and improvement in clinical outcomes. Given the size and duration of studies required to demonstrate differences in ultimate clinical outcomes for these issues, studies that assess well-established intermediate outcomes may be adequate, particularly given potentially higher priority gaps in the literature. In addition, there is not a strong reason to believe that process outcome linkages would differ for the general and SMI populations. However, incorporation of disease-specific symptom and physical function measures would be feasible and should be strongly considered in future trials.

### KQ 4

Among the four studies reviewed, there was relatively little diversity in the types of models tested, with most models based on Wagner’s Chronic Care Model. Elements of PCMH, other than those that overlap with the chronic care model, were not generally evaluated. Other models, including community-based care approaches may hold promise but were not evaluated in this review. At this early stage in the development of interventions to improve general medical outcomes, researchers and policymakers should remain open to alternative models.

With cardiovascular disease being a main source of morbidity and mortality in the general population and particularly in individuals with SMI, the focus on this category of disease is important. However, a greater variety of chronic disease outcomes is missing in the literature. Finally, there was relatively little evidence regarding individuals with schizophrenia and related psychotic disorders.

Important gaps in the literature were identified in our review. These gaps are further discussed in the Recommendations for Future Research section below.

## LIMITATIONS

The term “serious mental illness” varies in definition—an issue that makes it challenging to study this population through systematic reviews. Serious mental illness is not a MeSH search term, making searches of electronic databases challenging. Although we used broad and sensitive search strategies across multiple databases and augmented the searches by reviewing the bibliographies of selected articles, our search strategy may still have missed relevant articles. Three of the four studies were conducted in VA settings, possibly limiting applicability outside of nonintegrated health care systems.

In addition to the above limitations, our methodological approach had important strengths. First, limiting our review to evidence gleaned from clinical trials and quasi-experimental studies allowed us to focus on quality over quantity when examining this relatively undeveloped body of research. In addition, our evidence synthesis was guided by a carefully designed standardized protocol, including a systematic search of research databases and relevant bibliographies, double data abstraction, and use of validated criteria to assess the quality of identified studies. Further, we searched for evidence of publication bias in ClinicalTrials.gov. In sum, this was a highly structured and systematic review of the extant evidence.

## RECOMMENDATIONS FOR FUTURE RESEARCH

The combination of the known gaps in the quality of general medical care and subsequent outcomes in this population, together with the few relevant studies identified, confirms the importance of future research in this area. Proven interventions that close gaps in quality and can be implemented widely are needed. The ultimate goal is to improve general medical outcomes for individuals with serious mental illnesses; however none of the studies identified reports distal clinical outcomes, such as disease-specific symptom measures or disease-specific or all-cause mortality rates. Future research should include longer-term follow up and patient important clinical outcomes, particularly in the absence of a strong process – outcome association for intermediate outcomes.

SMIs encompass a wide variety of psychopathologies. Individuals with various psychiatric diagnoses within this broad group may, by virtue of the nature of their psychiatric symptoms, have differences in their experience of general medical care, leading to disparate outcomes among these subgroups. Individuals with bipolar disorder comprised two of the four studies identified here. A considerable amount of research has been conducted in the VHA and elsewhere that demonstrates significant disparities in outcomes and quality measures for individuals with other disorders, including and perhaps especially, schizophrenia and related disorders. Yet, studies here included a relatively small number of individuals with these disorders identified, with no analyses conducted by subgroup. While some methods to improve integration of care for individuals with SMI may be generalized among these diagnostic entities, some may need to be more specific to the psychiatric diagnostic group. Future research could focus on integration of psychiatric and general medical care for individuals with schizophrenia and related disorders as well as other diagnostic subgroups.

With the exception of the study by Bauer and colleagues (2006),55,56,58 all of the identified studies were conducted in one site, and all of the studies identified used clinical staff funded through research studies. Larger studies in more naturalistic, real-world settings are needed to evaluate the effectiveness, as opposed to efficacy, of the strategies tested. The models used in the studies in this review could be described broadly as:

1. Co-location of primary care services in the mental health setting.60
2. Optimization of treatment for psychiatric illness through collaborative care in the mental health setting with enhanced enrollment in and collaboration with primary care.55,56,58
3. Modification of the collaborative care model for psychiatric illness to specifically address common general medical issues seen in individuals with SMI.57,59
4. Nurse care management, focused on general medical issues, provided in the mental health setting to increase information exchange, access to primary care, and collaboration with primary care providers.54

The VA Cooperative Studies Program provides an valuable infrastructure for testing the effectiveness of larger scale implementation of these models, perhaps using RCTs with randomization at the site level. A large multicenter study might also allow for disaggregation of effects of various model components.

While our systematic review intentionally excluded interventions delivered in the community, the mental health outcomes associated with assertive community treatment emphasize the effectiveness of community-based interventions in this population. Assertive community treatment, implemented in the VA as Mental Health Intensive Case Management, operates under multiple principles, including that most services are provided within the team as opposed to being brokered out to other providers. The inclusion of a primary care provider, integrated into the workings of an assertive community treatment team, has not been studied as a platform for delivery of primary care services to this population. The model used in Druss and colleagues (2010)54 could be applied to the assertive community treatment model, with case managers having increased emphasis on coordination of services for general medical illnesses and disease registries implemented to assure preventive services are delivered. While we limited studies in this review to those conducted in traditional mental health outpatient settings, services delivered in the community may also be important to improving general medical care in this population.

Additional sites of delivery of mental health services focusing on individuals with SMI could potentially be targets for studying the addition of services oriented toward general physical health. For example, in the VA, Psychosocial Rehabilitation and Recovery Centers (PRRCs) provide treatment and rehabilitation services to Veterans with SMI. The addition of primary care services and the impact of wellness-oriented activities could be studied in PRRCs. Also, some VA Community Based Outpatient Centers (CBOCs) have developed integrated care programs. There may be a ready opportunity to conduct a high-quality observational study comparing these centers to CBOCs without integrated care programs.

By design, our review did not address disparities in quality of care received by individuals with SMI in general medical inpatient settings. Gaps in quality of care may also exist in inpatient care received by individuals with SMI, as has been shown for myocardial infarction32 and in receipt of and outcomes after nonemergency surgical procedures.75 These issues were beyond the scope of the current review but may be important topics for future systematic reviews.