# RESULTS

## LITERATURE FLOW

We reviewed 1598 titles and abstracts from the electronic search and an additional 24 from reference mining for a total of 1622 references. After applying inclusion/exclusion criteria at the abstract level, 1565 references were excluded. We retrieved 57 full-text articles for further review, after which another 50 articles were excluded. We identified a total of seven articles for inclusion in the current review, representing four RCTs. Four articles contained the main outcomes of the RCTs, and three articles, referred to as “companion articles,” contained additional data pertinent to the four RCTs. We grouped the studies by KQ. Figure 2 details the exclusion criteria at the full-text level and the number of articles related to each of the KQs.

Figure 2 Literature flow diagram

Abbreviations: KQ = key question; RCT = randomized controlled trial; SMI = serious mental illness

Additionally, our search of www.clinicaltrials.gov identified 208 potentially relevant trials. Of these, four were RCTs and one was a non-RCT of integrated care treatments for individuals with SMI. One of these trials was completed, published, and identified in our MEDLINE search.54 The other four studies have yet to be completed. Since we did not identify any registered and completed but unpublished trials, there was no evidence in this database of publication bias. The identified trial studies, along with one additional observational study identified through contacts with experts, are summarized in KQ 4.

Figure 2 illustrates each step of our literature search process. Appendix E provides a complete listing of articles excluded at the full-text stage, with reasons for exclusion.

## STUDY CHARACTERISTICS

Basic characteristics of the included studies are summarized in Table 2. Four good-quality RCTs (891subjects) met eligibility criteria; no quasi-experimental studies met eligibility criteria. The psychiatric diagnoses of interest (schizophrenia, schizoaffective disorder, and bipolar disorder) varied in proportion in each study, with two samples55–59 entirely consisting of patients with bipolar disorder and another sample60 with 21 to 34 percent carrying the diagnoses of interest. Another study54 included 49 percent with the diagnoses of interest. Druss and colleagues (2001)54 reported that 72 to 80 percent of the sample had “severe psychiatric illness” as defined by criteria of the National Advisory Mental Health Council.61

Table 2 Summary of included studies

Study | Design | Subjects | | Setting | Intervention summary | Followup | General medical outcomes | Quality
| | Disorder | Demographics
Druss et al., 2001^60^ | RCT with usual care control N = 120 | - Schizophrenia: 21%; - PTSD: 29%; - Major affective disorder: 13%; - Substance use: 28%; - “Severe psychiatric illness” by NAMHC criteria: 76% | - Gender: 0.8% female; - Mean age (yr): 45.2 +/− 8.2; - Race: 70% white | VA outpatient mental health | Co-located general medical clinic with care provided by a nurse practitioner with supervision from a family practitioner. Care coordination provided by a nurse. | 52 wk | U.S. Preventive Services Task Force indicators; general medical service use | Good
Bauer et al., 2006^55,56^ Kilbourne et al., 2009^58^ (VA Cooperative Study) | RCT with usual care control N = 306 | - Bipolar disorder type I: 87%; - Bipolar disorder type II: 13% | - Gender: 28% female; - Mean age (yr): 46.6 +/− 10.1; - Race: 71% “minority” | VA outpatient mental health | Specialty team of psychiatrist and nurse care manager, including self- management support, decision support, emphasis on primary care enrollment and collaboration | 156 wk | SF-36 Physical Health | Good
Kilbourne et al., 2008^57,59^ | RCT with usual care control N = 58 | - Bipolar disorder type I: 76%; - Bipolar disorder type II: 7%; - Bipolar disorder NOS: 17% | - Gender: 9% female; - Mean age (yr): 55.3+/− 8.4; - Race: 10% African American | VA outpatient mental health | Bipolar disorder medical care model consisting of 4 sessions self-management support, nurse care management, guideline implementation related to cardiovascular risk factors | 24 wk | SF-12 quality of life–physical health; WHO-DAS | Good
Druss et al., 2010^54^ | RCT with usual care control N = 407 | - Schizophrenia/schizoaffective disorder: 36.4%; - Bipolar disorder: 13.1%; - PTSD: 5.1%; - Depression: 45.2%; - Other: 0.3%; - Co-occurring substance use disorder: 26% | - Gender: 48.4% female; - Mean age (yr): 46.7 +/− 8.1; - Race: 77.4% African American; - Hispanic or Latino: 1.5%; - White: 21.1% | Urban community mental health center | Nurse care management with self-management, liaison, and case management components | 52 wk | RAND Community Quality Index; SF- 36; Framingham Cardiac Index | Good

Abbreviations: NAMHC = National Advisory Mental Health Council; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SF-36 = Short Form-36; VA = Veterans Affairs; WHO-DAS = World Health Organization Disability Assessment Schedule; wk = week/weeks

Three studies54,57,59,60 tested interventions specifically aimed at improving general medical outcomes, while one study55 focused primarily on psychiatric pathology but included an emphasis on primary care enrollment and collaboration. Care management or care coordination was a common element in the studies; only one study employed co-location of medical and psychiatric services.

Three studies55,57,59,60 were conducted in VA outpatient mental health settings, and one study was conducted in an urban community mental health center.54 Samples in VA settings had relatively few female participants (ranging from 0.8 to 29%) while almost one-half the sample was female in the urban community mental health center study. Participants were, on average, mid-life adults; mean ages ranged from 47 to 55 years of age. Followup varied from 24 to 156 weeks. A summary of the detailed quality assessment of the studies is found in Appendix C.

## KEY QUESTION 1 What types of care models have been evaluated prospectively that integrate mental health care and primary medical care with the goal of improving general medical outcomes for individuals with serious mental illness (SMI)?

### Studies of Efficacy

Our review identified four RCTs that met our inclusion criteria. Classification of the models of care used in these studies was informed by Wagner’s Chronic Care model.51,62–64 The models of care used in two studies55–59 were explicitly based on Wagner’s model. A third study 54 also utilized these principles, while the fourth study60 did not state a clear theoretical model on which it was based.

As required in our inclusion criteria, all the interventions were based primarily in a mental health setting, but integration of general medical services varied from services contiguous with the mental health clinic60 to care management provided from remote locations.55–59 Three studies54–59 relied on research funds to pay the key staff used for the study intervention, while one study60 was conducted in a setting where the psychiatry service paid the salaries of the staff involved in the intervention through clinical funds. The spectrum of clinical disciplines employed in the interventions of the four RCTs was relatively narrow and limited to those trained traditionally with a primary biomedical orientation (e.g., physicians, nurses, nurse practitioners). All the study interventions employed team-based care—at least to the extent of collaboration by multiple providers to help patients with their mental health and general medical problems. None of the studies used fully integrated teams of mental health and general medical providers working closely together with regular team meetings.

In Table 3 and the paragraphs that follow, each intervention is summarized relative to the components of Wagner’s Chronic Care Model.

Table 3 SMI intervention characteristics informed by Wagner’s Chronic Care Model

Study | Model elements
Study | Primary provider | Team-based | Enhanced access | Self-management support | Decision support | Delivery system | Information systems | Community linkages
Druss et al., 2001^60^ | Primary care: yes Psychiatric care: per usual care procedures | Supervising family practitioner and nurse practitioner; liaison with mental health providers | Primary care appointments scheduled to immediately follow mental health appointments when possible | None reported | None reported | Co-location of mental health and primary care services | VA computerized record (both study arms) | None reported
Bauer et al., 2006^55,56^ Kilbourne et al., 2009^58^ (VA Cooperative Study) | Primary care: per usual care procedures Psychiatric care: nurse care manager for bipolar disorder specific care; otherwise per usual care procedures | Primary care: emphasis on primary care enrollment and collaboration; otherwise per usual care procedures Psychiatric care: “specialty team” comprised of a psychiatrist and nurse care coordinator | Nurse care manager provided same day telephone and next business day clinic appointments | Psychoeducational program (Life Goals Program) primarily addressing bipolar disorder symptoms | Simplified VA Bipolar Clinical Practice Guidelines for providers | Care management; Bipolar Disorders Program | VA computerized record (both study arms) | None reported
Kilbourne et al., 2008^57,59^ | Primary care: per usual care procedures Psychiatric care: nurse care manager as first response for bipolar disorder specific care; otherwise per usual care procedures | Nurse care manager provided liaison between existing providers | None reported | Four-session group lead by nurse care manager | Continuing medical education and guidelines; pocket cards for medical and mental health providers related to cardiovascular risk factor management | Care management; Bipolar Disorder Medical Care Model | VA computerized record (both study arms) | None reported
Druss et al., 2010^54^ | Primary care and mental health care: per usual care procedures | Nurse care manager provided liaison between mental health and medical providers | None reported | Care manager provided motivational interviewing, development of action plans, and coaching | None reported | Care management | None reported | Public transportation and child care

Abbreviations: VA = Veterans Affairs

Druss and colleagues (2001)60 conducted a good-quality RCT evaluating a co-located, integrated medical clinic contiguous with the existing mental health outpatient clinic versus usual care in a VA medical center. Continuity of primary medical care was provided by a team that included a nurse practitioner who was supervised by a family practitioner, a nurse case manager, and an administrative assistant. The family practitioner acted as a liaison between the physicians in the medical and psychiatry services. Enhanced access was provided by reminder calls, followup after missed appointments, and efforts to schedule primary care visits immediately following mental health visits. Providers in both the intervention and usual care arms of the study had access to the VA’s electronic medical record system including records from all care in the VA system. The study intervention did not include additional decision support or community linkages. This study intervention was not reported as being designed according to an explicitly stated theoretical model.

Investigators in the VA Cooperative Study55,56,58 conducted a multisite, good-quality RCT to evaluate the effectiveness of the Bipolar Collaborative Chronic Care Model versus usual care in 11 VA medical centers. The delivery system was a “specialty team” located in the outpatient mental health setting and consisted of a psychiatrist who worked in collaboration with the nurse care coordinator. The nurse care coordinator provided enhanced access to mental health care with same-day telephone visits and next-business-day clinic visits. While focused primarily on management of bipolar disorder symptoms, the study intervention also emphasized enrollment in primary care and collaboration with medical providers 55 utilizing the nurse care manager. Self-management support, focused on bipolar disorder, was provided through a psychoeducational group (Life Goals Program) led by the nurse care coordinator over the first year of the intervention. Decision support, again primarily related to bipolar disorder, was implemented by providing the psychiatrists a one-page summary and a six-page manual of the VA Bipolar Clinical Practice Guidelines. Providers in both the intervention and usual care arms of the study had access to the VA’s electronic medical record system. The study intervention did not include community linkages. This study intervention was based on Wagner’s Chronic Care Model and also drew on elements from the PCMH with a stated patient-centered focus on care for bipolar disorder.

Kilbourne and colleagues (2008)57,59 conducted a good-quality RCT that evaluated an intervention using existing services for medical and psychiatric care in a VA medical center mental health outpatient setting augmented by the bipolar disorder medical care model, emphasizing self-management, care management, and guidelines implementation compared to usual care. The intervention began with providing four 3-hour sessions aimed at enhancing self-management of bipolar disorder along with general medical issues relevant to cardiovascular disease. Upon completion of these sessions, nurse case managers provided continuous care management by acting as a liaison among patients and existing medical and psychiatric providers. Decision support was implemented through two 1-hour continuing medical education sessions for providers of medical and psychiatric care focused on the unique aspects of cardiovascular risk factors in individuals with bipolar disorder as well as strategies for managing these risk factors based on the American Diabetes Association and American Heart Association guidelines. Pocket cards were also provided to reinforce material in these sessions. Providers in both the intervention and usual care arms of the study had access to the VA’s electronic medical record system including records from all care in the VA system. The study intervention did not include elements of enhanced access or community linkages. The study intervention was based largely on Wagner’s Chronic Care Model.

Druss and colleagues (2010)54 conducted a good-quality RCT evaluating medical care management using a registered nurse care manager in an urban community mental health center setting compared to usual care. The nurse care manager functioned not as a member of a team, but rather served as a liaison between medical and mental health providers. Patient self-management skills were supported through motivational interviewing, development of action plans, and coaching to help patients become more active in their own health care. Participants were linked to community resources for child care and public transportation to appointments. The study did not report that access to primary care providers was explicitly enhanced, though system level barriers were addressed by assisting eligible patients to enroll in entitlement programs. The study intervention did not include additional decision support or enhancement of information systems.

### Summary of Findings

The four studies represented in our review were similar in many ways, showing a relatively limited variety of approaches to improving general medical care. All studies used nurse care or case managers to some extent to augment or facilitate care provided by physicians or nurse practitioners. Notably, disciplines such as psychologists, with expertise in facilitating behavior change, and nutritionists were not incorporated into the models tested. As described above, three of the four studies had substantial basis in the Chronic Care Model, but elements of PCMH, such as having a primary treating provider, team-based care, and enhanced access, were not robustly employed. Three of the four studies were set in the VA system, while one was a non-VA study.

## KEY QUESTION 2 Do models of integrated care for individuals with SMI improve the process of care for preventive services (e.g., colorectal cancer screening) and chronic disease management (e.g., annual eye examination in patients with diabetes mellitus [DM]?

### Studies of Efficacy

Two good-quality trials54,60 provided data relevant to KQ 2. Process of care outcomes are summarized for preventive services (Table 4) and chronic disease management (Table 5). At baseline, the quality of general medical care was low, leaving ample room for intervention effects. In both studies, a high proportion (52 to 54%) of medical diagnoses were not documented previously in the medical record, and in one study,60 only about 20 percent of recommended preventive services had been provided prior to study start.54

Table 4 Process of care outcomes for preventive care (KQ 2)

Study | Design | Intervention summary | Preventive care
Study | Design | Intervention summary | Immunizations | | Screening procedures
Druss et al., 2001^60^ (additional preventive care results reported) | RCT | Co-located general medical clinic with care provided by a nurse practitioner with supervision from a family practitioner. Care coordination provided by a nurse. | [underlined: Intervention]; - Flu: 32.2%; - Pneumovax: 11.9% | [underlined: Control]; - Flu:11.5%; - Pneumovax: 32.8% | [underlined: Intervention]; - Hemoccult: 49.2%; - Digital rectal exam: 65.9%; - Flexible sigmoidoscopy: 33.9% | [underlined: Control]; - Hemoccult: 44.3%; - Digital rectal exam: 44.3%; - Flexible sigmoidoscopy: 14.8%
Druss et al., 2010^54^ (additional preventive care results reported) | RCT | Nurse care management with self-management, liaison, and case management components. | [underlined: Intervention] 24.7%^a^ | [underlined: Control] 3.8%^a^ | [underlined: Intervention] 50.4%^b^ | [underlined: Control] 21.6%^b^

a Rate reported is percentage of recommended immunizations performed (influenza; hepatitis B; measles, mumps, and rubella; pneumococcal bacterial infection; tetanus-diphtheria; and varicella).

b Rate reported is percentage of recommended screening tests performed (cholesterol, fecal blood, HIV, sigmoid, and tuberculosis).

Abbreviation: RCT = randomized controlled trial

Table 5 Process of care outcomes for chronic disease management (KQ 2)

Study | Design | Intervention summary | Chronic disease management
Study | Design | Intervention summary | Intervention | Control
Druss et al., 2001^60^ | RCT | Co-located general medical clinic with care provided by a nurse practitioner with supervision from a family practitioner. Care coordination provided by a nurse. | - (At 12 mo) Diabetes screening: 71.2%; - Cholesterol screening: 79.7%; - Weight measured?: 84.7%; - Smoking education 84.7% | - Diabetes screening: 45.9%; - Cholesterol screening: 57.4%; - Weight measured: 59.0%; - Smoking education: 63.9%
Druss et al., 2010^54^ | RCT | Nurse care management with self-management, liaison, and case management components. | - Proportion of indicated services received for cardiovascular disease: 34.9%^a^; - Framingham Cardiac Index: 6.9% | - Proportion of indicated services received for cardiovascular disease: 27.7%; - Framingham Cardiac Index: 9.8%

a Rate reported is the proportion indicated of services received for cardiovascular disease among the subset with at least one cardiometabolic condition (diabetes, hypertension, hypercholesterolemia, or coronary artery disease).

Abbreviation: RCT = randomized controlled trial

In both studies, the intervention improved preventive care as measured by receipt of immunizations and screening tests. Druss and colleagues (2001)60 reported higher influenza vaccination rates in the intervention versus usual care group (32.2% versus 11.5%, p = 0.006), while more subjects in usual care versus intervention received the pneumococcal vaccination (32.8% versus 11.9%, p = 0.006). This latter difference was not statistically significant in the subgroup with an indication for pneumococcal vaccination.

Selected screening tests were also more likely to be performed in the intervention group than in the usual care group: digital rectal examination (69.5% versus 44.3%, p = 0.005) and flexible sigmoidoscopy (33.9% versus 14.8%, p = 0.01).60 The investigators also reported a nonsignificant difference favoring the intervention for hemoccult testing (49.2% versus 44.3%, p = 0.10). In the more recent study,54 a broader set of general medical process measures were evaluated. Immunization outcomes were reported as the proportion of recommended services received (influenza; hepatitis B; measles, mumps, and rubella; pneumococcal; tetanus-diphtheria; and varicella). The intervention group was more likely to receive indicated vaccinations than the usual care group (24.6% versus 3.8%, p < 0.001). In addition, other recommended screening services (cholesterol, fecal occult blood, HIV, sigmoidoscopy, and tuberculosis testing) were completed more frequently in the intervention than usual care group (50.4% versus 21.6%, p < 0.001).54

The effects of the intervention on chronic disease management focused on process outcomes relevant to cardiovascular disease risk. Druss and colleagues (2001)60 reported significantly higher rates in the intervention group for weight measurement, diabetes screening, cholesterol screening, and smoking education. In the intervention group, these services were provided to 71.2 to 84.7% percent of the subjects by study end compared to 45.9 to 63.9 percent in the usual care group. In the later study,54 Druss and colleagues found higher rates of indicated services for cardiovascular disease (34.9 versus 27.7%, p = 0.03) in the intervention group in an analysis established a priori of a subset of 202 subjects who had one or more cardiometabolic conditions (diabetes, hypertension, hypercholesterolemia, or coronary artery disease). In the subset with blood tests available, the Framingham Cardiac Index (a measure of the 10-year risk of myocardial infarction or coronary-related death) was also significantly lower in the intervention group at study end (6.9 versus 9.8%, p = 0.03), with the intervention group’s index improving and the usual care group’s index worsening during the course of the study. However, an analysis that adjusted for baseline cardiovascular risk did not show a statistically significant change in risk between groups.

### Summary of Findings

Only two of the four studies identified for this review reported on measures relevant to KQ 2. Generally, the study interventions improved process measures for preventive services, and cardiovascular disease management. However, some measures represented a “low bar,” such as measuring weight rather than evaluating the quality of care for weight control. Other measures of relevant care processes (e.g., physical activity counseling) were not reported. Although rates of recommended services were improved by the intervention, they remained suboptimal in all groups at study end.

## KEY QUESTION 3 (3a) Do models of integrated care for individuals with SMI improve general functional status outcomes (e.g., as measured by SF-36) or disease-specific functional status outcomes (e.g., Seattle Angina Questionnaire) related to medical care for chronic medical conditions such as DM, hypertension, or heart failure? (3b) Do models of integrated care for individuals with SMI improve clinical outcomes related to preventive services (e.g., influenza rates) and chronic medical care (e.g., kidney disease, amputations, retinopathy in patients with coexisting DM)?

### Studies of Efficacy

Four good-quality studies met our criteria for KQ 3a. All studies measured general functional status outcomes, described in Table 6. Of these, three used the SF-36 item Short-Form Survey65–67 and one used the SF-12 item Short-Form Survey.68 Neither disease-specific symptom scales nor disease-specific functional status scales were reported in any of the studies. In addition, none of the four trials met our criteria for KQ3b by reporting clinical outcomes related to preventative services (e.g., incidence of influenza illness) or chronic medical care (e.g., diabetic retinopathy). Brief descriptions of relevant outcomes for each study are described below. Table 7 summarizes outcomes.

Table 6 Outcome measures

Measure | General class | Items measured | Scoring range; population mean (SD) | Direction for better outcomes
SF-36 | 36-item Short Form Health Survey | Physical functioning, role limitations due to physical health problems, bodily pain, general health | 0 to 100; 50 (10) | Higher scores indicate better outcomes
SF-12 | 12-item Short Form Health Survey | Physical functioning, role limitations due to physical health problems, bodily pain, general health | 0 to 100; 50 (10) | Higher scores indicate better outcomes

Table 7 Outcome summary for KQ 3

Study | Followup | Intervention versus control outcome
Druss et al., 2001^60^ | 52 weeks | SF-36 physical component: mean 50.9 (SD 7.1) vs. 45.3 (SD 9.7); p <0.001 for difference in change scores using baseline, 6-month and 12-month assessments
Bauer et al., 2006^55,56^ Kilbourne et al., 2009^58^ (VA Cooperative Study) | 156 weeks | SF-36 physical component: mean 43.4 (95% CI, 42.4 to 44.4) vs. 42.9 (95% CI, 41.9 to 43.9)
Kilbourne et al., 2008^57,59^ | 12 weeks 24 weeks | SF-12 physical component: mean 38.5 (SD 8.4) vs. 33.9 (SD 8.6), p = NR SF-12 physical component: mean 37.0 (SD 7.3) vs. 35.1 (SD 7.7), p = NR; difference in change scores using baseline, 3 month and 6 month assessments: 2.5, 95% CI, 0.5 to 4.9
Druss et al., 2010^54^ | 52 weeks | SF-36 physical component: mean 37.1 (SD 11.5) versus 34.7 (SD 11.9); p < 0.08; difference in change scores: “not significant,” p value not reported

Abbreviation: CI = confidence interval; NR = not reported; p = probability; SD = standard deviation; SF = Short Form

Druss and colleagues (2001)60 reported scores at 52-week followup on the physical health component of the SF-36 Short-Form Survey. Mean scores were higher for the intervention than for usual care group (50.9 [SD 7.1] versus 45.3 [SD 9.7], p = NR). The difference in change between the two groups was significant (t_170_ = 3.7, P<0.001), with subjects in the integrated care clinic scoring 4.7 points higher than baseline in the physical component summary score compared to a 0.3 point decline from baseline in the score of subjects in the general medicine clinic. Higher scores indicated better functional status, and a five-point difference is generally considered a clinically important difference.

Kilbourne and colleagues (2008)57,59 used the physical health component of the SF-12 Short-Form Survey to report functional outcomes after 24 weeks of the bipolar disorder medical care model versus usual care. The bipolar disorder medical care intervention did not address general medical problems directly but emphasized enrollment in and collaboration with primary care. Change in SF-12 scores from baseline to 24-week follow up differed significantly between intervention and control groups (intervention change in score = 0.8 [SD 6.7] versus control change in score −0.6 [SD 6.6]; p = 0.04).

Investigators in the VA Cooperative Study55,56,58 as well as Druss and colleagues (2010)54 also reported on functional outcomes using the SF-36 questionnaire. In the VA Cooperative Study, there was no statistically significant difference at 3-year followup between the Bipolar Collaborative Chronic Care Model and usual care groups on the SF-36 physical health component (mean = 43.4, 95% confidence interval [CI], 42.4 to 44.4 versus mean = 42.9, 95% CI, 41.9 to 43.9). Similarly, Druss and colleagues (2010)54 did not report a statistically significant difference between the mean scores of intervention versus usual care group on the SF-36 physical health component, although their findings exhibited a trend toward significance. At 1-year followup, SF-36 physical component scores were 37.1 (SD 11.5) and 34.7 (SD 11.9) for the medical care management and usual care groups respectively (p = 0.08). They also noted that the difference in change between the two group scores was not statistically significant (intervention group +1.9% versus usual care group −2.8%). This Druss study was the only one of the four reviewed that focused on an urban community mental health center and did not include veterans.

### Summary of Findings

In summary, the findings from two good-quality RCTs provided support for small improvements in general functional outcomes at followup periods ranging up to 52 weeks. Two other RCTs did not find statistically significant differences using similar health outcome survey measures when comparing integrated care to usual care. Thus, effects on physical function appear small and inconsistent. However, interventions varied in their focus on care processes that could be expected to improve physical function. Followup periods ranged from 24 to 156 weeks, and interventions that focus primarily on preventive care could be expected to require long followup periods to show positive effects on physical functioning. Three of the four studies were conducted in the VA system, with two of three VA studies demonstrating improvements in general functional outcomes. Given the range of medical services generally offered on site at VA health care locations, integration and collocation approaches may be easier to implement, and VA interventions generalize more easily to VA settings.

We did not identify published trials or quasi-experimental studies examining clinical outcomes relating to preventative services.

## KEY QUESTION 4 What are the gaps in evidence for determining how best to integrate care to improve general medical outcomes for individuals with SMI?

Only four trials, comprising 891 individuals, were identified by this review. The relatively small number of trials and limited range of outcomes reported make definitive conclusions difficult. Further, the small number of trials makes it difficult to identify the key elements of the interventions. We summarize the gaps in evidence in Table 8 and then discuss these gaps further.

Table 8 Summary of gaps in evidence

The key intervention components are uncertain.
There is greater uncertainty about intervention effects for individuals with SMIs other than bipolar disorder.
Effects on clinical outcomes have not been studied.
Sustainability of intervention effects is uncertain.
Effects of interventions (effectiveness) are uncertain when part of routine care rather than part of an RCT.
Effects of current VA delivery models are uncertain, including primary care services co-located in the mental health setting and assertive community treatment.
There is uncertainty about effects of current VA programs to improve mental health outcomes of veterans with SMI (e.g., assertive community treatment) that theoretically may have beneficial effects on general medical outcomes.

Abbreviation: RCT = randomized controlled trial; SMI = serious mental illness; VA = Veterans Affairs

The four RCTs included in our review, as reported in KQ 1, offered interventions with multiple components—with all components offered to those receiving the intervention. These study designs did not permit disaggregation of intervention effects for each intervention component.

Because two studies focused entirely on individuals with bipolar disorder, the proportion of studies with other SMIs was relatively few, with just 19 percent of the overall samples identified as having schizophrenia or schizoaffective disorder. The two studies that included individuals with SMI other than bipolar disorder did not provide subgroup analyses by diagnosis, so possible differences in the efficacy of the study interventions between diagnostic groups is unknown. Global Assessment of Functioning was reported in only one trial and only by study assignment group, so it was not possible to determine the overall number of individuals who met our study criteria based on level of functioning.

None of the four trials provided information on general medical outcomes, such as rates of diabetic neuropathy, influenza, or myocardial infarction, that occurred in study populations either during the delivery of the study intervention or in follow-up. While many measures selected for process of preventive care and quality of chronic disease management are known to be correlated with clinical outcomes, absence of this information is a substantial gap in the evidence. It may be possible, particularly for the three studies conducted in VA settings, to obtain additional follow-up data on general medical outcomes on study subjects.

Three of the four studies54,57,60 evaluated interventions implemented at only one site. Only one study60 explicitly stated that existing staff or resources were used in the study intervention, with the other trials delivering interventions with staff funded with research grants. Therefore, the RCTs reviewed primarily provided evidence regarding efficacy of the study interventions under ideal and closely controlled conditions. Information about the effectiveness of these interventions when implemented in existing programs was lacking.

All of the studies included in this review were RCTs with randomization at the patient level. No studies were identified using other designs stated in our inclusion criteria, such as cluster randomized trials, nonrandomized cluster controlled trials, controlled before-and-after studies, or interrupted time series designs. These additional designs can yield different types of information from the patient-level RCT, given that they are most often conducted in natural environments, thus producing fewer threats to external validity. For example, three of the four RCTs were conducted in single sites where motivation of the researchers and clinicians was likely to be high. Multisite designs might provide broader information on the effectiveness of the interventions in more naturalistic settings.

Two models of delivery of care that have already been implemented in the VA are relevant to our study questions: programs with co-located mental health and primary care and assertive community treatment programs. Mental health–primary care programs, which serve veterans with SMI in a clinic organized under the mental health service and are often co-located with mental health clinics, have been implemented in 10 out of 107 VA medical centers, based on a national survey of mental health leaders. After adjustment for organizational and patient-level factors, analyses of data from these programs showed that patients from co-located clinics received better quality of care compared with those without co-location on four of nine indicators. The study showed a need for additional chronic disease management strategies in these co-located clinics, given that HgA1c was actually less well controlled in these clinics compared to those without co-location. Another study using VA data in these co-located clinics, compared to those without co-location, showed a significant reduction in hospitalizations for ambulatory care–sensitive conditions.69,70 Additional evaluation of these programs, even retrospectively, has the potential to provide valuable information relevant to our study questions, including filling some of the gaps in evidence identified here (e.g., lack of quasi-experimental designs, broader diversity of included subjects based on diagnosis, and reporting of general medical outcomes).

Assertive community treatment—implemented in the VA as Mental Health Intensive Case Management (MHICM)—has been shown to be effective in reducing symptom severity and inpatient psychiatric utilization among individuals with SMI; client-reported housing, quality of life, satisfaction with services are improved.71 Though these programs, and their evaluation, to date have been focused on mental health outcomes, case managers do facilitate receipt of primary care services to varying degrees—yet general medical outcomes of patients receiving MHICM and other assertive community treatment implementations have been largely unreported.

It is notable that the collaborative care models for bipolar disorder employed in two of the studies 55,57 have gained sufficient evidence to be included in the recommendations of two recent clinical treatment guidelines.72,73 Still, the impact of these models on general medical outcomes remains an area where additional study is needed.

Our search of www.clinicaltrials.gov identified three RCTs and one observational study evaluating integrated approaches to addressing the general medical needs of individuals with SMI. One of these studies is being conducted in VHA. These studies are summarized in Table 9.

Table 9 Ongoing studies evaluating integrated approaches

Study title | VA/DOD population? | Intervention | Comparator | Sponsor and ClinicalTrials.gov ID number | Funding start and stop date | Status
Life Goals Behavioral Change to Improve Outcomes for Veterans With Serious Mental Illness | Y | Behavioral: life goals collaborative care | Usual care | Department of Veterans Affairs NCT01244854 | October 2010 to December 2011 | Enrolling by invitation
Treatment of Metabolic Syndrome in a Community Mental Health Center | N | IMBED: active comparator—a primary care provider Liaison: Active comparator—a medical case manager | Treatment as usual; no intervention | The University of Texas Health Science Center at San Antonio NCT01115114 | January 2009 to September 2012 | Recruiting
The Medical HOME Study | N | Care team | No intervention; referral only | National Institute of Mental Health NCT01228032 | April 2010 to January 2015 | Recruiting
Non-RCT
Reduction of Cardiovascular Risk in Severe Mental Illness (RISCA-TMS) | N | Nurse-administered lifestyle counseling | None | Consorci Hospitalari de Vic NCT01182012 | August 2010 to December 2012 | Recruiting
Benefits of a Primary Care Clinic Co- located and Integrated in the Mental Health Setting for Veterans with Serious Mental Illness | Y | Enrollment in a co- located, integrated primary care clinic in the mental health outpatient unit | Subject is own comparator; time- series design | Systems Outcomes and Quality in Chronic Disease and Rehabilitation; Providence VA Medical Center | Unfunded | Completed; manuscript in press

Abbreviations: RCT = randomized controlled trial